# References

Abadi, Azar M., Yeongjin Gwon, Matthew O. Gribble, Jesse D. Berman, Rocky Bilotta, Mike Hobbins, and Jesse E. Bell, “Drought and All-Cause Mortality in Nebraska from 1980 to 2014: Time-Series Analyses by Age, Sex, Race, Urbanicity and Drought Severity,” Science of the Total Environment, Vol. 840, 2022.
Akushevich, I., A. Yashkin, M. Kovtun, J. Kravchenko, K. Arbeev, and A. I. Yashin, “Forecasting Prevalence and Mortality of Alzheimer’s Disease Using the Partitioning Models,” Experimental Gerontology, Vol. 174, 2023.
Alexeeff, Stacey E., Gabriele G. Pfister, and Doug Nychka, “A Bayesian Model for Quantifying the Change in Mortality Associated with Future Ozone Exposures Under Climate Change,” Biometrics, Vol. 72, 2016.
Al-Shihabi, Fatima, Anna Moore, and Tahseen A. Chowdhury, “Diabetes and Climate Change,” Diabetic Medicine, Vol. 40, 2023.
Alzheimer’s Association, “What Is Alzheimer’s Disease?” webpage, undated. As of August 28, 2024: https://www.alz.org/alzheimers-dementia/what-is-alzheimers
Alzheimer’s Association, “2024 Alzheimer’s Disease Facts and Figures,” Alzheimer’s and Dementia, Vol. 20, No. 5, May 2024.
American Heart Association, “What Is Cardiovascular Disease?” webpage, undated. As of August 28, 2024: https://www.heart.org/en/health-topics/consumer-healthcare/what-is-cardiovascular-disease
Anderson, G. Brooke, and Michelle L. Bell, “Heat Waves in the United States: Mortality Risk during Heat Waves and Effect Modification by Heat Wave Characteristics in 43 U.S. Communities,” Environmental Health Perspectives, Vol. 119, 2011.
Archer, Elizabeth J., Craig Baker-Austin, Timothy J. Osborn, Natalia R. Jones, Jaime Martínez-Urtaza, Joaquín Trinanes, James D. Oliver, Felipe J. Colón González, and Iain R. Lake, “Climate Warming and Increasing Vibrio Vulnificus Infections in North America,” Scientific Reports, Vol. 13, 2023.
Arias, P.A., N. Bellouin, E. Coppola, R. G. Jones, G. Krinner, J. Marotzke, V. Naik, M. D. Palmer, G.-K. Plattner, J. Rogelj, “Technical Summary,” in V. Masson-Delmotte, P. Zhai, A. Pirani, S. L. Connors, C. Péan, S. Berger, N. Caud, Y. Chen, L. Goldfarb, M. I. Gomis, M. Huang, K. Leitzell, E. Lonnoy, J. B. R. Matthews, T. K. Maycock, T. Waterfield, O. Yelekçi, R. Yu, and B. Zhou, eds., Climate Change 2021: The Physical Science Basis. Contribution of Working Group I to the Sixth Assessment Report of the Intergovernmental Panel on Climate Change, Cambridge University Press, 2021.
Bell, Sue Anne, Theodore J. Iwashyna, Xingyu Zhang, Bingxin Chen, and Matthew A. Davis, “All-Cause Hospitalizations After Large-Scale Hurricanes Among Older Adults: A Self-Controlled Case Series Study,” Prehospital and Disaster Medicine, Vol. 36, 2021.
Bell, Sue Anne, Marie Lynn Miranda, Julie P. W. Bynum, and Matthew A. Davis, “Mortality After Exposure to a Hurricane Among Older Adults Living with Dementia,” JAMA Network Open, Vol. 6, 2023.
Berberian, Alique G., David J. X. Gonzalez, and Lara J. Cushing, “Racial Disparities in Climate Change–Related Health Effects in the United States,” Current Environmental Health Reports, Vol. 9, 2022.
Blum, Matthew F., Yijing Feng, G. Brooke Anderson, Dorry L. Segev, Mara McAdams-Demarco, and Morgan E. Grams, “Hurricanes and Mortality Among Patients Receiving Dialysis,” Journal of the American Society of Nephrology, Vol. 33, 2022.
Blum, Matthew F., Yijing Feng, Cascade P. Tuholske, Byoungjun Kim, Mara A. McAdams Demarco, Brad C. Astor, and Morgan E. Grams, “Extreme Humid-Heat Exposure and Mortality Among Patients Receiving Dialysis,” American Journal of Kidney Diseases, in press.
Bobb, Jennifer F., Ziad Obermeyer, Yun Wang, and Francesca Dominici, “Cause-Specific Risk of Hospital Admission Related to Extreme Heat in Older Adults,” JAMA, Vol. 312, 2014.
Bongioanni, Paolo, Renata Del Carratore, Silvia Corbianco, Andrea Diana, Gabriella Cavallini, Silvia M. Masciandaro, Marco Dini, and Roberto Buizza, “Climate Change and Neurodegenerative Diseases,” Environmental Research, Vol. 201, 2021.
Burke, Marshall, Anne Driscoll, Sam Heft-Neal, Jiani Xue, Jennifer Burney, and Michael Wara, “The Changing Risk and Burden of Wildfire in the United States,” Proceedings of the National Academy of Sciences, Vol. 118, 2021.
Carnes, Bruce A., David Staats, and Bradley J. Willcox, “Impact of Climate Change on Elder Health,” The Journals of Gerontology: Series A, Vol. 69, 2014.
CDC—See Centers for Disease Control and Prevention.
Centers for Disease Control and Prevention, “Heart Disease Facts,” webpage, undated-a. As of August 28, 2024: https://www.cdc.gov/heart-disease/data-research/facts-stats/index.html
Centers for Disease Control and Prevention, “Heat and Pregnancy,” webpage, undated-b. As of August 28, 2024: https://www.cdc.gov/extreme-heat/risk-factors/heat-and-pregnancy.html
Centers for Disease Control and Prevention, “Leading Causes of Death,” webpage, undated-c. As of August 28, 2024: https://www.cdc.gov/nchs/fastats/leading-causes-of-death.htm
Centers for Disease Control and Prevention, “Most Recent National Asthma Data,” webpage, undated-d. As of August 28, 2024: https://www.cdc.gov/asthma/most_recent_national_asthma_data.htm
Centers for Disease Control and Prevention, Chronic Kidney Disease in the United States, 2023, May 2023.
Cheng, Jian, Zhiwei Xu, Hilary Bambrick, Vanessa Prescott, Ning Wang, Yuzhou Zhang, Hong Su, Shilu Tong, and Wenbiao Hu, “Cardiorespiratory Effects of Heatwaves: A Systematic Review and Meta-Analysis of Global Epidemiological Evidence,” Environmental Research, Vol. 177, 2019.
Clayton, Susam “Climate Change and Mental Health,” Current Environmental Health Reports, Vol. 8, No. 1, 2021.
ClevelandClinic, “Cardiovascular Disease,” webpage, undated. As of August 28, 2024: https://my.clevelandclinic.org/health/diseases/21493-cardiovascular-disease
Cohen, Daryl, “94.7M Americans Live in Coastline Regions,” America Counts: Stories, U.S. Census Bureau, July 15, 2019.
Cronin, Robert E., and Robert F. Reilly, “Unfractionated Heparin for Hemodialysis: Still the Best Option,” Seminars in Dialysis, Vol. 23, 2010.
Davis, Robert E., Elizabeth K. Driskill, and Wendy M. Novicoff, “The Association between eather and Emergency Department Visitation for Diabetes in Roanoke, Virginia,” International Journal of Biometeorology, Vol. 66, 2022.
Debbage, Neil, and J. Marshall Shepherd, “The Urban Heat Island Effect and City Contiguity,” Computers, Environment and Urban Systems, Vol. 54, 2015.
Edelson, Paul J., Rachel Harold, Joel Ackelsberg, Jeffrey S. Duchin, Steven J. Lawrence, Yukari C. Manabe, Matt Zahn, and Regina C. Larocque, “Climate Change and the Epidemiology of Infectious Diseases in the United States,” Clinical Infectious Diseases, Vol. 76, 2023.
Einzinger, Patrick, Ruth Leskovar, and Claudia Wytrzens, “A Comparison of System Dynamics and Markov Models for Cost-Effectiveness Analysis of Chronic Diseases,” in Proceedings of the International Workshop on Innovative Simulation for Health Care, Backfrieder, Bruzzone, Longo, Novak, Rosen, eds., 107–14, DIME Università di Genova, 2012.
EPA—See U.S. Environmental Protection Agency.
FDA—See U.S. Food and Drug Administration.
Federal Emergency Management Agency, “Hurricane,” webpage, undated. As of August 28, 2024: https://community.fema.gov/ProtectiveActions/s/article/Hurricane
Flores, Aaron B., Timothy W. Collins, Sara E. Grineski, and Jayajit Chakraborty, “Disparities in Health Effects and Access to Health Care Among Houston Area Residents After Hurricane Harvey,” Public Health Reports, Vol. 135, 2020.
Fuchs, Flávio D., and Paul K. Whelton, “High Blood Pressure and Cardiovascular Disease,” Hypertension, Vol. 75, 2020.
Fyfe, J., B. Fox-Kemper, R. Kopp, and G. Garner, “Summary for Policymakers of the Working Group I Contribution to the IPCC Sixth Assessment Report—Data for Figure SPM.8 (v20210809),” NERC EDS Centre for Environmental Data Analysis, 2021. As of August 28, 2024: 10.5285/98af2184e13e4b91893ab72f301790db
Gasparrini, Antonio, Yuming Guo, Masahiro Hashizume, Eric Lavigne, Antonella Zanobetti, Joel Schwartz, Aurelio Tobias, Shilu Tong, Joacim Rocklöv, Bertil Forsberg, Michela Leone, Manuela De Sario, Michelle L. Bell, Yue-Liang Leon Guo, Chang-Fu Wu, Haidong Kan, Seung-Muk Yi, Micheline De Sousa Zanotti Stagliorio Coelho, Paulo Hilario Nascimento Saldiva, Yasushi Honda, Ho Kim, and Ben Armstrong, “Mortality Risk Attributable to High and Low Ambient Temperature: A Multicountry Observational Study,” The Lancet, Vol. 386, 2015.
GBD Chronic Kidney Disease Collaboration, “Global, Regional, and National Burden of Chronic Kidney Disease, 1990–2017: A Systematic Analysis for the Global Burden of Disease Study 2017,” The Lancet, Vol. 395, No. 10225, February 29, 2020.
Gorris, Morgan E., Kathleen K. Treseder, Charles S. Zender, and James T. Randerson, “Expansion of Coccidioidomycosis Endemic Regions in the United States in Response to Climate Change,” GeoHealth, Vol. 3, No. 10, October 2019.
Gronlund, Carina J., Kyle P. Sullivan, Yonathan Kefelegn, Lorraine Cameron, and Marie S. O’Neill, “Climate Change and Temperature Extremes: A Review of Heat- and Cold-Related Morbidity and Mortality Concerns of Municipalities,” Maturitas, Vol. 114, 2018.
Guirguis, Kristen, Rupa Basu, Wael K. Al-Delaimy, Tarik Benmarhnia, Rachel E. S. Clemesha, Isabel Corcos, Janin Guzman-Morales, Brittany Hailey, Ivory Small, Alexander Tardy, Devesh Vashishtha, Joshua G. Zivin, and Alexander Gershunov, “Heat, Disparities, and Health Outcomes in San Diego County’s Diverse Climate Zones,” GeoHealth, Vol. 2, 2018.
Gutierrez, Miguel Pardinas, Paquita Zuidema, Mehdi Mirsaeidi, Michael Campos, and Naresh Kumar, “Association Between African Dust Transport and Acute Exacerbations of COPD in Miami,” Journal of Clinical Medicine, Vol. 9, 2020.
Ha, Sandie, Kelly Nguyen, Danping Liu, Tuija Männistö, Carrie Nobles, Seth Sherman, and Pauline Mendola, “Ambient Temperature and Risk of Cardiovascular Events at Labor and Delivery: A Case-Crossover Study,” Environmental Research, Vol. 159, 2017.
Harvard Medical School, “Target Heart Rate on a Beta Blocker,” webpage, undated. As of August 28, 2024: http://www.health.harvard.eduwww.health.harvard.edu/heart-health/target-heart-rate-on-a-beta-blocker
HHS—See U.S. Department of Health and Human Services.
Homer, Jack B., and Gary B. Hirsch, “System Dynamics Modeling for Public Health: Background and Opportunities,” American Journal of Public Health, Vol. 96, 2006.
Howard, David, Rebecca Zhang, Yijian Huang, and Nancy Kutner, “Hospitalization Rates Among Dialysis Patients During Hurricane Katrina,” Prehospital and Disaster Medicine, Vol. 27, 2012.
Howard, Luke, The Climate of London, [1883] 2012.
Huang, Wenzhong, Yuan Gao, Rongbin Xu, Zhengyu Yang, Pei Yu, Tingting Ye, Elizabeth A. Ritchie, Shanshan Li, and Yuming Guo, “Health Effects of Cyclones: A Systematic Review and Meta-Analysis of Epidemiological Studies,” Environmental Health Perspectives, Vol. 131, 2023.
Human Mortality Database, “U.S.A. Total Population,” webpage, undated. As of August 28, 2024: https://www.mortality.org/Country/Country?cntr=USA
Iman, Ronald L., Jon C. Helton, and James E. Campbell, “An Approach to Sensitivity Analysis of Computer Models: Part II—Ranking of Input Variables, Response Surface Validation, Distribution Effect and Technique Synopsis,” Journal of Quality Technology, Vol. 13, 1981.
Institute for Health Metrics and Evaluation, “Global Burden of Disease (GBD),” webpage, undated. As of August 28, 2024: https://www.healthdata.org/research-analysis/gbd
IPCC—See Intergovernmental Panel on Climate Change.
Jaffe, Dan, Duli Chand, Will Hafner, Anthony Westerling, and Dominick Spracklen, “Influence of Fires on O3 Concentrations in the Western US,” Environmental Science & Technology, Vol. 42, 2008.
Johnson, Sandra Leigh, “New Estimates Show U.S. Population Growth Continues to Slow,” America Counts: Stories, U.S. Census Bureau, December 30, 2019.
Jung, Chau-Ren, Yu-Ting Lin, and Bing-Fang Hwang, “Ozone, Particulate Matter, and Newly Diagnosed Alzheimer’s Disease: A Population-Based Cohort Study in Taiwan,” Journal of Alzheimer’s Disease, Vol. 44, 2015.
Khalili, Roxana, Scott M. Bartell, Xuefei Hu, Yang Liu, Howard H. Chang, Candice Belanoff, Matthew J. Strickland, and Verónica M. Vieira, “Early-Life Exposure to PM2.5 and Risk of Acute Asthma Clinical Encounters Among Children in Massachusetts: A Case-Crossover Analysis,” Environmental Health, Vol. 17, 2018.
Khatana, Sameed Ahmed M., Rachel M. Werner, and Peter W, Groeneveld. 2022, “Association of Extreme Heat and Cardiovascular Mortality in the United States: A County-Level Longitudinal Analysis from 2008 to 2017,” Circulation, Vol. 146, 2022.
Kim, Ejin, Hyuk Huh, Yongwon Mo, Jae Yoon Park, Jiyun Jung, Hajeong Lee, Sejoong Kim, Dong Ki Kim, Yon Su Kim, and Chun Soo Lim, “Long-Term Ozone Exposure and Mortality in Patients with Chronic Kidney Disease: A Large Cohort Study,” BMC Nephrology, Vol. 25, 2024.
Kim, Sun-Young, Esther Kim, and Woo Jin Kim, “Health Effects of Ozone on Respiratory Diseases,” Tuberculosis and Respiratory Diseases, Vol. 83, 2020.
Kolbe, Allison, and Trini Beleche, Linking Medical Product Manufacturing Locations with Natural Hazard Risk: Implications for the Medical Product Supply Chain, Office of the Assistant Secretary for Planning and Evaluation, U.S. Department of Health and Human Services July 2024.
Kovesdy, Csaba P., “Epidemiology of Chronic Kidney Disease: An Update 2022,” Kidney International Supplements, Vol. 12, 2022.
Leffers, Jeanne M., “Climate Change and Health of Children: Our Borrowed Future,” Jopurnal of Pediatric Health Care, Vol. 35, No. 1, 2022.
Levi, Marcel, “Hemostasis and Thrombosis in Extreme Temperatures (Hypo- and Hyperthermia),” Seminars in Thrombosis and Hemostasis, 2018.
Levy, Karen, Shanon M. Smith, and Elizabeth J. Carlton, “Climate Change Impacts on Waterborne Diseases: Moving Toward Designing Interventions,” Current Environmental Health Reports, June 2019.
Li, Xing, Qing Chen, Xueyan Zheng, Yongzhi Li, Min Han, Tao Liu, Jianpeng Xiao, Lingchuan Guo, Weilin Zeng, Junfeng Zhang, and Wenjun Ma, “Effects of Ambient Ozone Concentrations with Different Averaging Times on Asthma Exacerbations: A Meta-Analysis,” Science of The Total Environment, Vol. 691, 2019.
Limaye, Vijay S., Wendy Max, Juanita Constible, and Kim Knowlton, “Estimating the Health-Related Costs of 10 Climate-Sensitive U.S. Events During 2012,” GeoHealth, Vol. 3, 2019.
Lin, Cynthia, Timothy Wade, and Elizabeth Hilborn, “Flooding and Clostridium Difficile Infection: A Case-Crossover Analysis,” International Journal of Environmental Research and Public Health, Vol. 12, 2015.
Lynch, Victoria D., and Jeffrey Shaman, “Waterborne Infectious Diseases Associated with Exposure to Tropical Cyclonic Storms, United States, 1996–2018,” Emerging Infectious Diseases, Vol. 29, 2023.
Makrufardi, Firdian, Amja Manullang, Desy Rusmawatiningtyas, Kian Fan Chung, Sheng-Chieh Lin, and Hsiao-Chi Chuang, “Extreme Weather and Asthma: A Systematic Review and Meta-Analysis,” European Respiratory Review, Vol. 32, 2023.
Manisalidis, Ioannis, Elisavet Stavropoulou, Agathangelos Stavropoulos, and Eugenia Bezirtzoglou, “Environmental and Health Impacts of Air Pollution: A Review,” Frontiers in Public Health, Vol. 8, 2020.
Masson-Delmotte, V., P. Zhai, A. Pirani, S. L. Connors, C. Péan, S. Berger, N. Caud, Y. Chen, L. Goldfarb, M. I. Gomis, M. Huang, K. Leitzell, E. Lonnoy, J. B. R. Matthews, T. K. Maycock, T. Waterfield, O. Yelekçi, R. Yu, and B. Zhou, eds., Climate Change 2021: The Physical Science Basis. Contribution of Working Group I to the Sixth Assessment Report of the Intergovernmental Panel on Climate Change, Cambridge University Press, 2021.
Mazidi, Mohsen, and John R. Speakman, “Predicted Impact of Increasing Average Ambient Temperature over the Coming Century on Mortality from Cardiovascular Disease and Stroke in the USA,” Atherosclerosis, Vol. 313, 2020.
Medical News Today, “Metoprolol, Oral Tablet,” webpage, undated. As of August 28, 2024: https://www.medicalnewstoday.com/articles/metoprolol-oral-tablet#about
Monaghan, Andrew J., Sean M. Moore, Kevin M. Sampson, Charles B. Beard, and Rebecca J. Eisen, “Climate Change Influences on the Annual Onset of Lyme Disease in the United States,” Ticks and Tick-Borne Diseases, Vol. 6, 2015.
Monsour, Molly, Emily Clarke-Rubright, Wil Lieberman-Cribbin, Christopher Timmins, Emanuela Taioli, Rebecca M Schwartz, Samantha S. Corley, Anna M Laucis, and Rajendra A Morey, “The Impact of Climate Change on the Prevalence of Mental Illness Symptoms,” Journal of Affective Disorders, March 2022.
Morgado, Michele E., Chengsheng Jiang, Jordan Zambrana, Crystal Romeo Upperman, Clifford Mitchell, Michelle Boyle, Amy R. Sapkota, and Amir Sapkota, “Climate Change, Extreme Events, and Increased Risk of Salmonellosis: Foodborne Diseases Active Surveillance Network (FoodNet), 2004–2014,” Environmental Health, Vol. 20, 2021.
NASEM—See National Academies of Science, Engineering, and Medicine.
National Academies of Science, Engineering, and Medicine, Building Resilience into the Nation’s Medical Product Supply Chains, 2022.
National Center for Biotechnology Information, “PubChem Compound Summary for CID 2083, Albuterol,” webpage, undated-a. As of August 28, 2024: https://pubchem.ncbi.nlm.nih.gov/compound/Albuterol
National Center for Biotechnology Information, “PubChem Compound Summary for Heparin,” webpage, undated-b. As of August 28, 2024: https://pubchem.ncbi.nlm.nih.gov/compound/Heparin
National Center for Health Statistics, “Mortality in the United States, 2022,” NCHS Data Brief, No. 492, March 2024.
National Institute of Diabetes and Digestive and Kidney Diseases, “Kidney Disease Statistics for the United States, Fast Facts on Kidney Disease,” webpage, undated-a. As of August 28, 2024: https://www.niddk.nih.gov/health-information/health-statistics/kidney-disease
National Institute of Diabetes and Digestive and Kidney Diseases, “What Is Chronic Kidney Disease?” webpage, undated-b. As of August 28, 2024: https://www.niddk.nih.gov/health-information/kidney-disease/chronic-kidney-disease-ckd/what-is-chronic-kidney-disease
National Institute of Diabetes and Digestive and Kidney Diseases, End Stage Renal Disease, 2023.
National Institute on Aging, “How Is Alzheimer’s Disease Treated?” webpage, undated. As of August 28, 2024: https://www.nia.nih.gov/health/alzheimers-treatment/how-alzheimers-disease-treated
National Kidney Foundation, “Hemodialysis,” webpage, undated. As of August 28, 2024: https://www.kidney.org/atoz/content/hemodialysis#:~:text=In%20a%20dialysis%20center%2C%20hemodialysis,for%20shorter%20hours%20each%20time
National Oceanic and Atmospheric Administration, “Wildfire Climate Connection, ” webpage, last updated July 24, 2023. As of September 4, 2024: https://www.noaa.gov/noaa-wildfire/wildfire-climate-connection
National Oceanic and Atmospheric Administration, National Centers for Environmental Information, “U.S. Climate Summary for June 2024,” July 11, 2024.
Neumann, James E., Susan C. Anenberg, Kate R. Weinberger, Meredith Amend, Sahil Gulati, Allison Crimmins, Henry Roman, Neal Fann, and Patrick L. Kinney, “Estimates of Present and Future Asthma Emergency Department Visits Associated with Exposure to Oak, Birch, and Grass Pollen in the United States,” GeoHealth, Vol. 3, 2019.
Next Foundry for American Biotechnology, Advanced Regenerative Manufacturing Institute, and Nexight Group, Essential Medicines Supply Chain and Manufacturing Resilience Assessment, U.S. Department of Health and Human Services, May 2022.
NIDDK—See National Institute of Diabetes and Digestive and Kidney Diseases.
NOAA—See National Oceanic and Atmospheric Administration.
Ortendahl, Jesse D., Allison L. Diamant, Peter P. Toth, Dasha Cherepanov, Amanda L. Harmon, and Michael S. Broder, “Protecting the Gains: What Changes Are Needed to Prevent a Reversal of the Downward Cardiovascular Disease Mortality Trend?” Clinical Cardiology, Vol. 42, 2019.
Parker, Eva Rawlings, “The Influence of Climate Change on Skin Cancer Incidence: A Review of the Evidence,” International Journal of Women’s Dermatology, Vol. 7, 2021.
Rasking, Leen, Kenneth Vanbrabant, Hannelore Bové, Michelle Plusquin, Katrien De Vusser, Harry A. Roels, and Tim S. Nawrot, “Adverse Effects of Fine Particulate Matter on Human Kidney Functioning: A Systematic Review,” Environmental Health, Vol., 21, 2022.
Remigio, Richard V., Chengsheng Jiang, Jochen Raimann, Peter Kotanko, Len Usvyat, Frank W. Maddux, Patrick Kinney, and Amir Sapkota, “Association of Extreme Heat Events with Hospital Admission or Mortality Among Patients with End-Stage Renal Disease,” JAMA Network Open, Vol. 2, 2019.
Rice, R. Byron, Katie Boaggio, Nicole E. Olson, Kristen M. Foley, Christopher P. Weaver, Jason D. Sacks, Stephen R. McDow, Amara L. Holder, and Stephen D. Leduc, “Wildfires Increase Concentrations of Hazardous Air Pollutants in Downwind Communities,” Environmental Science and Technology, Vol. 57, 2023.
Rowland, Sebastian T., Amelia K. Boehme, Johnathan Rush, Allan C. Just, and Marianthi-Anna Kioumourtzoglou, “Can Ultra Short-Term Changes in Ambient Temperature Trigger Myocardial Infarction?” Environment International, Vol. 143, 2020.
Salas, R. N., L. G. Burke, J. Phelan, G. A. Wellenius, E. J. Orav, and A. K. Jha, “Impact of Extreme Weather Events on Healthcare Utilization and Mortality in the United States,” Nature Medicine, Vol. 30, 2024.
Singh, Nidhi, Ashtyn Tracy Areal, Susanne Breitner, Siqi Zhang, Stefan Agewall, Tamara Schikowski, and Alexandra Schneider, “Heat and Cardiovascular Mortality: An Epidemiological Perspective,” Circulation Research, Vol. 134, 2024.
Soetaert, Karline, Thomas Petzoldt, and R. Woodrow Setzer, “Solving Differential Equations in R: PackagedeSolve,” Journal of Statistical Software, Vol. 33, 2010.
Soneja, Sutyajeet, Chengsheng Jiang, Jared Fisher, Crystal Romeo Upperman, Clifford Mitchell, and Amir Sapkota, “Exposure to Extreme Heat and Precipitation Events Associated with Increased Risk of Hospitalization for Asthma in Maryland, U.S.A,” Environmental Health, Vol. 15, 2016.
Song, Jian, Zhen Ding, Hao Zheng, Zhiwei Xu, Jian Cheng, Rubing Pan, Weizhuo Yi, Jing Wei, and Hong Su, “Short-Term PM1 and PM2.5 Exposure and Asthma Mortality in Jiangsu Province, China: What’s the Role of Neighborhood Characteristics?” Ecotoxicology and Environmental Safety, Vol. 241, 2022.
Stella, A. B., A. Galmonte, M. Deodato, S. Ozturk, J. Reis, and P. Manganotti, “Climate Change and Global Warming: Are Individuals with Dementia—Including Alzheimer’s Disease—at a Higher Risk?” Current Alzheimer’s Research, Vol. 20, 2023.
Straight Nursing, “All Aboard for Albuterol,” webpage, undated. As of August 28, 2024: https://straightanursingstudent.com/albuterol-administration/
Sun, Jian, Joshua S. Fu, Kan Huang, and Yang Gao, “Estimation of future PM_2.5_- and Ozone-Related Mortality over the Continental United States in a Changing Climate: An Application of High-Resolution Dynamical Downscaling Technique,” Journal of the Air & Waste Management Association, Vol. 65, 2015.
Sun, Shengzhi, Keith R. Spangler, Kate R. Weinberger, Jeff D. Yanosky, Joseph M. Braun, and Gregory A. Wellenius, “Ambient Temperature and Markers of Fetal Growth: A Retrospective Observational Study of 29 Million U.S. Singleton Births,” Environmental Health Perspectives, Vol. 127, No. 6, 2019.
Swerdel, Joel N., Teresa M. Janevic, Nora M. Cosgrove, and John B. Kostis, “The Effect of Hurricane Sandy on Cardiovascular Events in New Jersey,” Journal of the American Heart Association, Vol. 3, 2014.
Tavera Busso, Iván, Ana Carolina Mateos, Luis Isaías Juncos, Norma Canals, and Hebe Alejandra Carreras, “Kidney Damage Induced by Sub-Chronic Fine Particulate Matter Exposure,” Environment International, Vol. 121, Part 1, December 2018.
Tee Lewis, P. Grace, Weihsueh A. Chiu, Ellu Nasser, Jeremy Proville, Aurora Barone, Cloelle Danforth, Bumsik Kim, Jolanda Prozzi, and Elena Craft, “Characterizing Vulnerabilities to Climate Change Across the United States,” Environment International, Vol. 172, 2023.
Tsao, C. W., A. W. Aday, Z. I. Almarzooq, “Heart Disease and Stroke Statistics—2023 Update: A Report From the American Heart Association,” Circulation, 2023.
U.S. Census Bureau, “Population Projections,” webpage, undated. As of August 28, 2024: https://www.census.gov/programs-surveys/popproj.html
U.S. Department of Health and Human Services, “Extreme Heat,” webpage, undated. As of August 28, 2024: https://www.hhs.gov/climate-change-health-equity-environmental-justice/climate-change-health-equity/climate-health-outlook/extreme-heat/index.html
U.S. Environmental Protection Agency, “Climate Change Indicators: Heatwaves,” webpage, undated-a. As of August 28, 2024: https://www.epa.gov/climate-indicators/climate-change-indicators-heat-waves
U.S. Environmental Protection Agency, “Climate Change Indicators: Tropical Cyclone Activity,” webpage, undated-b. As of August 28, 2024: https://www.epa.gov/climate-indicators/climate-change-indicators-tropical-cyclone-activity
U.S. Environmental Protection Agency, “Climate Change Indicators: U.S. and Global Temperature,” webpage, undated-c. As of August 28, 2024: https:/www.epa.gov/climate-indicators/climate-change-indicators-us-and-global-temperature (https://www.epa.gov/climate-indicators/climate-change-indicators-us-and-global-temperature)
U.S. Environmental Protection Agency, “Climate Change Indicators: Weather and Climate,” webpage, undated-d.
U.S. Environmental Protection Agency, “Climate Change Indicators: Wildfires,” webpage, undated-e. As of August 28, 2024: https://www.epa.gov/climate-indicators/climate-change-indicators-wildfires
U.S. Environmental Protection Agency, “Particulate Matter (PM2.5) Trends,” webpage, undated-f. As of August 28, 2024: https://www.epa.gov/air-trends/particulate-matter-pm25-trends
U.S. Food and Drug Administration, “FY25 Legislative Proposals,” 2024. As of August 28, 2024: https://www.fda.gov/media/176924/download?attachment#:~:text=The%20FY%202025%20budget%20includes,%2C%20medical%20devices%2C%20and%20foods
U.S. Geological Survey, “Wildfire and Climate Change,” webpage, undated. As of August 28, 2024: https://www.usgs.gov/science-explorer/climate/wildfire
Vergadi, Eleni, Glykeria Rouva, Maria Angeli, and Emmanouil Galanakis, “Infectious Diseases Associated with Desert Dust Outbreaks: A Systematic Review,” International Journal of Environmental Research and Public Health, Vol. 19, 2022.
Wang, Bingyu, Ki-Do Eum, Fatemeh Kazemiparkouhi, Cheng Li, Justin Manjourides, Virgil Pavlu, and Helen Suh, “The Impact of Long-Term PM2.5 Exposure on Specific Causes of Death: Exposure-Response Curves and Effect Modification Among 53 Million U.S. Medicare Beneficiaries,” Environmental Health, Vol. 19, 2020.
Wang, Yifan, Siyao Xiao, Yuhan Zhang, Howard Chang, Randall V. Martin, Aaron Van Donkelaar, Audrey Gaskins, Yang Liu, Pengfei Liu, and Liuhua Shi, “Long-Term Exposure to PM2.5 Major Components and Mortality in the Southeastern United States,” Environment International, Vol. 158, 2022.
Wathanavasin, Wannasit, Athiphat Banjongjit, Jeerath Phannajit, Somchai Eiam-Ong, and Paweena Susantitaphong, “Association of Fine Particulate Matter (PM2.5) Exposure and Chronic Kidney Disease Outcomes: A Systematic Review and Meta-Analysis,” Scientific Reports, Vol. 14, 2024.
Wettstein Z. S., and A. Vaidyanathan, “Psychotropic Medication Prescriptions and Large California Wildfires,” JAMA Network Open, Vol. 7, No. 2, 2024.
Wilgus, May-Lin, and Maryum Merchant, “Clearing the Air: Understanding the Impact of Wildfire Smoke on Asthma and COPD,” Healthcare, Vol. 12, 2024.
World Health Organization, “Standard Classification of Medical Conditions,” webpage, undated. As of August 28, 2024: https://www.who.int/observatories/global-observatory-on-health-research-and-development/classifications/health-categories
Wu, Keyu, Hung Chak Ho, Hong Su, Cunrui Huang, Hao Zheng, Wenyi Zhang, Junwen Tao, Mohammad Zahid Hossain, Yunquan Zhang, Kejia Hu, Min Yang, Qiyue Wu, Zhiwei Xu, and Jian Cheng, “A Systematic Review and Meta-Analysis of Intraday Effects of Ambient Air Pollution and Temperature on Cardiorespiratory Morbidities: First Few Hours of Exposure Matters to Life,” eBioMedicine, Vol. 86, 2022.
Xi, Y., D. B. Richardson, A. V. Kshirsagar, T. J. Wade, L. Wyatt, G. C. Peterson, and A. G. Rappold. 2020. “Ambient PM2.5 Exposure and Mortality in U.S. End Stage Renal Disease Patients Receiving In-Center Hemodialysis: 2008–2014,” ISEE Conference Abstracts, 2020.
Xi, Yuzhi, David B. Richardson, Abhijit V. Kshirsagar, Timothy J. Wade, Jennifer E. Flythe, Eric A. Whitsel, Geoffrey C. Peterson, Lauren H. Wyatt, and Ana G. Rappold, “Effects of Short-Term Ambient PM2.5 Exposure on Cardiovascular Disease Incidence and Mortality Among U.S. Hemodialysis Patients: A Retrospective Cohort Study,” Environmental Health, Vol. 21, 2022.
Xu, Zhiwei, Shilu Tong, Jian Cheng, Yuzhou Zhang, Ning Wang, Yuqi Zhang, Alimila Hayixibayi, and Wenbiao Hu, “Heatwaves, Hospitalizations for Alzheimer’s Disease, and Postdischarge Deaths: A Population-Based Cohort Study,” Environmental Research, Vol. 178, 2019.
Yang, Li, Wenjie Wan, Caiyan Yu, Cheng Xuan, Pinpin Zheng, and Jing Yan, “Associations Between PM2.5 Exposure and Alzheimer’s Disease Prevalence Among Elderly in Eastern China,” Environmental Health, Vol. 21, 2022.
Yin, Peng, Ya Gao, Renjie Chen, Wei Liu, Cheng He, Junwei Hao, Maigeng Zhou, and Haidong Kan, “Temperature-Related Death Burden of Various Neurodegenerative Diseases Under Climate Warming: A Nationwide Modelling Study,” Nature Communications, Vol. 14, 2023.
Zhang, Yunquan, Qianqian Xiang, Yong Yu, Zhiying Zhan, Kejia Hu, and Zan Ding, “Socio-Geographic Disparity in Cardiorespiratory Mortality Burden Attributable to Ambient Temperature in the United States,” Environmental Science and Pollution Research, Vol. 26, 2019.
Zhao, Naizhuo, Lauren Pinault, Olaniyan Toyib, Jennifer Vanos, Michael Tjepkema, and Sabit Cakmak, “Long-Term Ozone Exposure and Mortality from Neurological Diseases in Canada,” Environment International, Vol. 157, 2021.