# About This Report

It is anticipated that extreme weather events due to climate change will increase the prevalence of a number of acute and chronic diseases. As a result, the demand for drugs to prevent or treat those conditions is likely to increase. If the anticipated increase in demand for these drugs is not planned for, already strained medical supply chains will be further strained, resulting in poor health outcomes among affected patient populations and additional costs to health systems.

In this study, we estimated how the anticipated effects of climate change on the prevalence of a sample of four chronic conditions will affect demand for drugs needed to treat them. To generate these estimates, we conducted an environmental scan of the peer-reviewed and grey literature and developed a medical condition–specific systems dynamics model.

This research was funded by the U.S. Department of Health and Human Services, Office of the Assistant Secretary for Planning and Evaluation, and was carried out in the Payment, Cost, and Coverage Program of RAND Health Care.

RAND Health Care, a division of RAND, promotes healthier societies by improving health care systems in the United States and other countries. We do this by providing health care decisionmakers, practitioners, and consumers with actionable, rigorous, objective evidence to support their most complex decisions. For more information, see www.rand.org/health-care, or contact

RAND Health Care Communications
- 1776 Main Street
- P.O. Box 2138
- Santa Monica, CA 90407-2138
- (310) 393-0411, ext. 7775
- RAND_Health-Care@rand.org