# Chapter 4 Discussion and Future Directions

## Discussion

From our environmental scan, we identified the following types of medical conditions that are climate-vulnerable: maternal-fetal health, CVD, asthma, COPD, water- and food-borne infectious diseases, fungal infections, vector-borne illnesses, mental health, cancer, stroke, Alzheimer’s disease and other neurodegenerative diseases, kidney disease, and diabetes. Many of these conditions are among the most common chronic conditions in the United States or among the top ten leading causes of death in the country.

The majority of the articles from our environmental scan focused on the impact of climate change on maternal-fetal health, CVD, asthma, COPD, vector-borne diseases, and CKD. The environmental scan also revealed that drugs used to treat many of these conditions have experienced past and/or current shortages. Our review revealed a significant knowledge gap regarding the impact of climate change on the demand for drugs to treat these and other conditions.

Many of the environmental scan articles included a discussion of the variability of climate change effects among different populations and geographic locations, highlighting the importance of keeping this variation in mind when considering climate-mitigating strategies so that resource planning is conducted with the highest-risk and highest-demand populations in mind. Furthermore, the shifting demographics of the U.S. population in the coming decades, particularly the aging population, will have a significant impact on how climate change interacts with health and drug demand in the future.

We evaluated the demand for one drug used to treat each of the four medical conditions under study: CVD, asthma, ESRD, and Alzheimer’s disease. Our systems dynamics model estimates significant changes in drug demand across all age groups under various climate change scenarios. As climate change intensifies, the model projects that drug demand will generally increase, except in cases where higher mortality rates lead to a decrease in demand. The model captures the combined effects of these factors, particularly how increased incidence and mortality due to climate change affect disease prevalence—and hence drug demand. This selection process is indirect, involving a shift in the age profile or distribution of disease. There is a dynamic interplay within each age group between increased incidence and increased mortality, which ultimately determines not only the prevalence for the given age group but also for subsequent older age groups.

The concept of selection effect is key to understanding how climate change influences disease prevalence outcomes—and ultimately drug demand. Selection effect refers to how changes in mortality rates under climate change reshape the composition of disease-affected populations. For CVD, increased mortality due to climate change disproportionately affects those in advanced disease stages, stabilizing or reducing prevalence in older age groups (65+ years), despite rising incidence rates. Similarly, asthma shows exacerbated prevalence in younger age groups because of heightened incidence and exacerbation, while higher mortality rates among severe cases in older age groups might stabilize or reduce prevalence over time.

In contrast, ESRD demonstrates sustained prevalence increases across all age groups under climate change, driven by a rising baseline incidence. Despite elevated mortality rates, the persistently high incidence of ESRD outweighs these effects, resulting in continued or exacerbated prevalence trends. This understanding of selection effects is crucial for anticipating future disease burdens and drug demand amid evolving environmental conditions. It emphasizes the need for health care and medical supply chain strategies that adapt, not only to disease incidence and mortality, but also to the dynamic shifts in disease prevalence driven by demographic changes and climate impacts.

## Future Directions

The results of our systems dynamic model need to be interpreted in the context of the previously outlined model limitations (see Chapter 3). Future work should assess how these limitations may bias the estimates and explore ways to address these limitations in future iterations of the model.

According to our literature review, existing models developed to predict the impact of climate change on future disease prevalence use various underlying assumptions, and evaluate impact on differing geographic units, time frames, or populations, which makes comparison of projected prevalence estimates across models (including comparison to our model) challenging. Our model is the first national-level model designed to predict drug demand changes under future climate scenarios. Building on our work, future research can develop a blueprint for climate change and health model inputs to create methodological consistency across studies and allow for cross-model comparisons.

Future versions of this model, which informs demand for drugs or medical products in response to health outcomes of climate, can focus on U.S. regions and populations at highest risk for climate-related weather events. Furthermore, future models can account for chronic disease progression or severity (and resultant impact on drug demand) and account for complex climate events where multiple extreme weather events need to be concurrently accounted for. The current model focuses on chronic conditions and assumes that people with these conditions will remain on the modeled drugs. Future work should examine acute conditions affected by climate change, such as Valley Fever and other infectious diseases, and short-term demand for related drugs. Importantly, future models should evaluate drug supply-demand dynamics and account for various drugs that can be interchangeably used to treat a given condition. As far as the effect of extreme temperature on health is concerned, most studies focused on extreme heat. Future studies should also focus on better understanding the effect of extreme cold weather on health and related drug demand.

With the model’s estimations, policymakers, manufacturers, suppliers, health care providers, and other key stakeholders may be able to have a clearer view of the potential anticipated future drug demand—and necessary innovations or strategies required to mitigate increased demand—under varying climate conditions. This could help trigger proactive strategies to build supply chain resiliency through advance planning—such as stockpiling, ensuring the availability of multiple supply chains for certain high-demand drugs, and on-shoring production, where appropriate. Ultimately, the model could be used to inform policies to mitigate climate change’s impact on demand by ensuring sufficient drug supply under various future climate scenarios.