# Chapter 3 Systems Dynamics Model

To understand how climate change might affect future demand for drugs, we developed a systems dynamics framework that can simulate and predict demand under various climate change scenarios (Homer and Hirsch, 2006). Through the simulation framework and scenario analysis, the model provides initial but valuable insights into the possible health impacts of climate change, and resultant changes in demand for drugs, which can help support informed decisionmaking for emergency preparedness and build supply chain resiliency. The model produces four key outcomes: (1) quantitative estimates of changes in prevalence of select medical conditions; (2) estimates of mortality due to specific climate change impacts; (3) identification of age groups most likely to be affected by climate change impacts; and (4) estimates of changes in demand for the sampled drugs used in treating the medical conditions under different climate change scenarios.

This chapter describes the sampling strategy for medical conditions and products that are the focus of the modeling effort, model design, inputs, assumptions, and limitations, and then presents the results of the analyses. Additional technical details about the model and data inputs are available in Appendixes B, C, and D.

## Methods

### Medical Condition and Drug Sampling Strategies

Our environmental scan yielded literature indicating that the following health conditions are climate-vulnerable: maternal-fetal health, CVD, asthma, COPD, water- and food-borne infectious diseases, fungal infections, vector-borne illnesses, mental health, cancer, stroke, Alzheimer’s disease and other neurodegenerative diseases, kidney disease, and diabetes. From this list, we selected asthma, CVD, end-stage renal disease, and Alzheimer’s, as described in more detail below. These are among the most common chronic diseases in the United States and among the top ten leading causes of death in the country. Furthermore, we prioritized conditions with related drugs that are first-line treatments and that had experienced past and/or current shortages according to the 2022 report Essential Medicines Supply Chain and Manufacturing Resilience Assessment (Next Foundry for American Biotechnology, Advanced Regenerative Manufacturing Institute, and Nexight Group, 2022), which was sponsored by the Administration for Strategic Preparedness and Response (formerly the Office of the Assistant Secretary for Preparedness and Response).

We used three criteria to sample the drugs used to treat the selected medical conditions. We prioritized drugs that are considered standard-of-care in the treatment of each medical condition, those that have experienced past and/or current shortages, and those with existing data regarding their baseline annual utilization in the United States. We also worked to select drugs that are largely indicated for the selected conditions or family of conditions. With these criteria, we selected four drugs: albuterol, metoprolol, heparin, and donepezil. All the sampled drugs have experienced past and/or current shortages, except for donepezil (Next Foundry for American Biotechnology, Advanced Regenerative Manufacturing Institute, and Nexight Group, 2022).

#### Cardiovascular Disease and Metoprolol

CVD refers to diseases of the heart and blood vessels (American Heart Association, undated). The term CVD includes a number of diseases, including coronary artery disease, congestive heart failure, stroke, and arrhythmia, among others (Cleveland Clinic, undated). CVD is among the most common chronic diseases in the United States and is the leading cause of death in the nation (CDC, undated-a; CDC, undated-c). Approximately 5 percent of Americans 20 years of age and older suffer from one or more forms of CVD (Tsao et al., 2023).

Metoprolol belongs to the beta-blocker class of anti-hypertensive drugs (Harvard Medical School, undated). Hypertension, or elevated blood pressure, is a risk factor for coronary artery disease, stroke, congestive heart failure, and other CVDs (Fuchs and Whelton, 2020). Therefore, metoprolol is used in patients with hypertension and for heart rate control (for example, in patients with atrial fibrillation) and for the treatment of congestive heart failure. Metoprolol is administered in oral and intravenous formulations (Medical News Today, undated).

#### Asthma and Albuterol

Asthma is a chronic condition that affects lung airways. It is among the most common chronic diseases in the United States (CDC, undated-c). As of 2021, 7.7 percent of the U.S. population suffered from asthma (National Center for Health Statistics, 2024).

Albuterol is a short-acting inhaled beta-agonist and is first-line in the treatment of individuals with asthma diagnosis (National Center for Biotechnology Information, undated-a). Albuterol is most commonly administered in powder form using an inhaler or in liquid form through an oral nebulizer (Straight Nursing, undated).

#### End-Stage Renal Disease and Heparin

CKD results from damage to the kidneys over time that prohibits the kidneys from effectively filtering blood (NIDDK, undated-b). If a kidney transplant is not possible or available, renal replacement therapy (RRT) through hemodialysis or peritoneal dialysis is the preferred treatment for patients with stage 5 CKD—also referred to as end-stage renal disease (ESRD). In the United States, about every two in 1,000 people have ESRD (NIDDK, undated-a). Patients with ESRD on hemodialysis generally need three sessions per week to ensure normal electrolyte levels in the bloodstream (National Kidney Foundation, undated). The absence of hemodialysis, or missed sessions, can lead to electrolyte imbalances that can result in cardiac arrhythmia and death (National Kidney Foundation, undated).

Hemodialysis requires unfractionated heparin to prevent clotting during the procedure (Cronin and Reilly, 2010; National Center for Biotechnology Information, undated-b). However, heparin is used in many other contexts to prevent clotting.

#### Alzheimer’s Disease and Donepezil

Alzheimer’s disease is a neurodegenerative disease and a type of dementia (Alzheimer’s Association, undated). It is among the top ten leading causes of death in the United States (CDC, undated-c).

Donepezil belongs to the cholinesterase inhibitor class of drugs that are considered first-line in the treatment of mild to moderate Alzheimer’s disease (National Institute on Aging, undated).

### Model Overview

We developed estimates for future drug demand from 2024 projected to 2040 under different climate impact assumptions for the four drugs, each considered first-line in treating one of four sampled conditions likely to be affected by climate change. Our approach utilizes a systems dynamics framework based on ordinary differential equations (ODEs) to simulate and predict future drug demand on a daily time scale. This method emphasizes causal relationships, dynamic interactions, and feedback loops. Systems dynamics models are deterministic (as opposed to stochastic), simulate continuous time (as opposed to discrete time), and incorporate transition rates between simulated states (as opposed to transition probabilities) (Einzinger, Leskovar, and Wytrzens, 2012). Using information from our environmental scan, we estimated medical condition prevalence trends and related drug demand time trends. Historical data informed the ranges of values for each model parameter, and we estimated the impact of key variables, such as temperature, precipitation, and air quality on disease prevalence (please see the subsection on “Climate Impacts”).

The core of our model consists of coupled ODEs that describe the rate of change in drug demand, accounting for climate change effects. To estimate demand changes specific to climate change effects, we developed a baseline model that assumes no change from current climate conditions but incorporates non-climate-related changes in disease prevalence and incidence rates, all-cause and disease-specific mortality rates, and population by age group. Details on the data sources and modeling approaches for each of these input variables is available in Appendix C. Given initial conditions, such as the initial prevalence of the disease and hazard rates for the risk of developing the disease across different age groups, the model integrates these dynamics to predict future prevalence, from which we can then derive the future demand for specific drugs.

To account for climate change scenarios and make comparisons relative to the baseline scenario, we adjusted the hazard rates for developing the diseases, all-other-cause mortality, and disease-specific mortality based on specific factors related to climate change factors. This was done through a two-step approach:

1. First, using estimates from the literature, we linked temperature projections under five emissions scenarios to three key climate factors: days of extreme heat, number of hurricanes reaching the U.S. mainland, and wildfire-associated air quality changes (increases in PM2.5 and ozone levels).
2. Second, we used statistical estimates from the literature to link these four climate factors to associated changes in health outcomes, including all-cause mortality, disease-specific mortality, and incidence rates of the sampled medical conditions.

The model integrates the modified hazard rates, mortality rates, and incidence rates assumed under various climate change scenarios, and, to account for uncertainties, we sampled the parameter values within their estimated uncertainty ranges. We ran 100 different simulations for each climate change scenario (detailed under “Model Outputs,” below) to generate a comprehensive set of possible outcomes and explore a wide range of potential future climate conditions.

### Model Design

The model design applied to all four diseases is identical. However, the models for each disease are informed by different data sources and inputs that influence how the various factors affecting the prevalence of these diseases change with climate change. For more information on the specific data sources and inputs used for each medical condition, see Appendix C.

Our model operates on a daily time scale from 2024 to 2040. As shown in Figure 3.1, our model consists of three compartments representing different states and population groups: the presumed Healthy Population (H), which includes all individuals not diagnosed with the disease; the Diagnosed and Treated Population (T), which consists of individuals diagnosed with the disease and receiving treatment; and the Deceased Population (D), which includes individuals who have died from any cause, including deaths attributable to the disease of interest. The model predicts the number of individuals in each compartment over time, broken down by age group.

Figure 3.1 Illustration of Model Compartments and Relationships

NOTE: π is the rate at which individuals enter the healthy population through migration or birth. Individuals from the healthy population compartment (H) may die or receive a diagnosis for the medical condition and treatment and ultimately die. The rate at which individuals from the healthy population compartment die from any cause is represented by μ_O_. The transition of individuals from the healthy compartment to the diagnosis and treated compartment is governed by age-specific hazard rates denoted by λ. The transition of individuals from the diagnosed and treated compartment (T) to the compartment of deceased population (D) is designated by μ_O_ plus μ_T_ where μ_O_ is the rate at which individuals from the healthy population compartment die and μ_T_ is the condition-specific mortality rate.

Figure 3.1 depicts model compartments and relationships. Our model consists of several compartments representing different states and population groups: the presumed Healthy Population open parenthesis upper case H close parenthesis, which includes all individuals not diagnosed with cardiovascular disease (for example); the Diagnosed and Treated Population open parenthesis upper case T close parenthesis, which consists of individuals diagnosed with cardiovascular disease and receiving treatment (for example, metoprolol); and the Deceased Population open parenthesis D close parenthesis, which includes individuals who have died from any cause, including cardiovascular disease-attributable deaths. In Figure 3.1, Pi is the rate at which individuals enter the healthy population through migration or birth. Individuals from the healthy population compartment may die or receive a diagnosis for the medical condition and treatment and ultimately die. The rate at which individual from the healthy population compartment die is represented by mu sub o. The transition of individuals from the healthy compartment to the diagnosis and treated compartment is governed by age specific hazard rates denoted by lambda. The transition of individuals from the diagnosed and treated compartment to the compartment of dead population is designated by mu sub o plus mu sub upper case T where mu sub o is the rate at which individuals from the healthy population compartment die and mu sub upper case T is the condition-specific mortality rate.

#### Climate Impacts

The model produces estimates of future disease prevalence across five climate scenarios, based on the Shared Socioeconomic Pathways (SSPs) developed in the Intergovernmental Panel for Climate Change’s (IPCC’s) Sixth Assessment Report (Masson-Delmotte et al., 2021). The SSPs are a set of five scenarios used by the IPCC to estimate future greenhouse gas (GHG) emissions under different levels of adoption of climate change mitigation and adaptation policies (Table 3.1). For the purposes of this study, these scenarios can be understood as being organized in order of least to highest severity of climate change.

Table 3.1 Climate Scenarios Used in the Model

Scenario Name | Scenario Description | Mean Global Temperature Change by 2040; (relative to 2024, degrees Celsius)
SSP 1–1.9 | Very low GHG emissions: CO2 emissions reach net zero around 2050 | 0.228
SSP 1–2.6 | Low GHG emissions: CO2 emissions reach net zero after 2050 | 0.297
SSP 2–4.5 | Intermediate GHG emissions: CO2 emissions around current levels until 2050 | 0.379
SSP 3–7.0 | High GHG emissions: CO2 emissions double by 2100 | 0.457
SSP 5–8.5 | Very high GHG emissions: CO2 emissions double by 2050 | 0.556

SOURCE: Scenario descriptions from Arias et al. (2021); mean global temperature changes derived from EPA (undated-c) and Masson-Delmotte et al. (2021).

Our model focused on four climate change factors that could be linked to health outcomes: extreme heat days, hurricanes making landfall in the United States, and wildfire-associated changes in air quality (including PM2.5 and ozone) (Table 3.2). While these are not the only climate-related events that may affect our medical conditions of interest, these four indicators were chosen based on the availability of data and existing research examining their effect on human health. In order to translate global temperature changes under each climate change scenario (Table 3.1) to changes in our four climate factors of interest, we first modeled U.S. temperature change as a function of global temperature change. Then, using historical temperature and climate data, we modeled future frequency of extreme heat days, number of hurricanes making landfall in the United States, and wildfire extent (thus wildfire-associated air quality changes). Additional details on the data sources and methods used to develop these estimates are available in Appendix C.

Table 3.2 Indicators Used to Represent Exposure to Climate Threats

Climate Event | Indicator
Extreme heat | - Annual number of extreme heat days
Precipitation | - Annual number of hurricanes making landfall in the United States
Air quality | - Average annual concentration of wildfire-related PM2.5; - Average annual concentration of wildfire-related ozone

#### Climate-Health Linkages

Estimates of the four climate threats above were then linked to disease-specific incidence and mortality using estimates from the literature. In some cases, the literature provided specific evidence for the relationship between event exposure and a health outcome (e.g., the relative risk of asthma mortality during a heat wave). In other cases, we had to use proxies such as condition-related hospitalizations due to a climate event to estimate our outcome variables. Full descriptions of each data source and linkage methodology used are available in Appendix C.

#### Model Outputs

To capture the relationships between temperature changes, extreme weather manifestations, and the outcomes of interest, we employ an experimental design incorporating a large sample of parameter values. Each relationship is characterized by estimates with uncertainty bounds. For our study, we generated 100 unique combinations of parameter values, each sampled within its specified uncertainty range. The 100 unique parameter combinations are sampled using the Latin Hypercube approach (Iman, Helton, and Campbell, 1981). This method efficiently explores the uncertainty space, ensuring a homogeneous sample consistent with the specified probability distribution functions for each input parameter. The model varied parameters linking climate effects to the manifestations of extreme weather events, and subsequently to disease-specific incidence and mortality rates, as well as all-cause mortality rates. The baseline scenario does not include variability since it assumes no climate change effects, keeping input parameters constant.

The model outputs include (1) the total population of healthy people, which includes individuals who have not been diagnosed with the disease, by age; (2) the prevalence of the disease, encompassing all individuals who have been diagnosed, categorized by age group; (3) the total aggregate number of deaths, accounting for both deaths caused by the disease and those from all other causes. Changes in prevalence estimates are considered equivalent to the future change in demand for the relevant medical products.

### Assumptions and Limitations

Our systems dynamics model, like all models, approximates reality and has limitations due to strategic simplifications, often driven by the lack of precise data. These simplifications should be considered when interpreting the results and should be addressed in future model iterations. Future work could focus on modeling efforts that address these limitations through refinement and research.

First, there are limitations in our modeling approach that arise from using a systems dynamics model. Our model’s dynamics are governed by a set of coupled ODEs that describe the population flows between compartments over time. This approach employs a deterministic framework, predicting the average population dynamics without accounting for random variations or individual differences within a given model compartment. Instead of tracking each individual separately, the model deals with population densities, focusing on the proportion or number of people in each compartment rather than following individual trajectories. The population is divided into compartments, each representing a specific state or condition (e.g., healthy, diagnosed). The model assumes that everyone within a compartment is identical in terms of health status and behavior, with transitions between compartments occurring according to predefined rates influenced by environmental factors and interventions. This does not take into account individual risk factors such as body mass index (BMI), differences in treatment adherence, disease exacerbation or natural progression, or health impacts on the undiagnosed population. The model also does not account for seasonal variation in disease incidence or mortality. Similarly, the model assumes that new births and immigrants are healthy and do not have a pre-existing disease diagnosis. Each of these simplifications may lead to over- or underestimation of disease prevalence and therefore future drug demand.

The model is also limited by the availability and granularity of relevant climate and health data sources. For example, we were unable to incorporate subnational geographic variation in climate variables. These heterogeneities were averaged in our model, resulting in broad error bounds in parameter estimates. In addition, we focused on a limited set of climate factors based on data availability; however, these do not provide a comprehensive picture of potential health impacts of climate change. Future work might identify additional data sources to incorporate a wider range of climate factors into future models.

Similarly, the limited number of studies examining the impacts of climate-related events on disease-specific incidence and mortality necessitated some simplifications and assumptions. For some of the medical conditions, we were unable to find direct data linking the extreme weather event in question with the incidence of the relevant disease; in such cases, we used proxies such as hospitalizations, disease events, or disease exacerbations and assumed that the rate of increase in true incidence would be similar to the proxy (see Appendix C). This may result in overestimations of future prevalence because hospitalizations can occur multiple times, unlike the one-time event of disease diagnosis, and in the case of Alzheimer’s disease, the extreme weather event may not lead to the development of the disease; rather it may cause adverse reactions that require the patient to seek medical attention.

The model builds on existing prevalence, incidence, and mortality data. While mortality data for each condition are available, incidence data are harder to obtain. Where incidence data were unavailable, we assumed stable prevalence based on historical data (see Appendix C). Self-reported prevalence data, as was used for CVD and estimates, may be less reliable than incidence or mortality data. Future work might explore additional data sources for these inputs to enhance robustness of the model.

Finally, the model focuses on future demand for one drug to treat each medical condition. Each of these medical conditions have other potential treatment options that are not accounted for in our model. The choice of drug used in the model is largely illustrative, as our model estimates demand as a function of disease prevalence. In reality, large increases in demand for specific drugs may result in shifts to alternative products. Future models might explore the more complex dynamics of how demand for all drugs treating a given medical condition might shift due to climate change impacts.

## Results

The model produced estimates of disease prevalence, all-cause mortality, and drug demand for four diseases across five climate scenarios. Overall, the model estimated increases in prevalence relative to the baseline scenario for three of the four modeled diseases: asthma, ESRD, and Alzheimer’s. In contrast, the model estimated decreases in prevalence relative to the baseline scenario for CVD due to increased mortality in older age groups due to climate change factors. These modeled changes in disease prevalence translate into parallel changes in drug demand, with a decreased overall demand for metoprolol (CVD), but increased overall demand for albuterol (asthma), heparin (ESRD), and donepezil (Alzheimer’s).

For each disease, we developed three key plots to illustrate our findings. The first plot (3.2a, 3.3a, 3.4a, 3.5a) shows the projected percentage change in disease prevalence from the initial year (2024) to the final year (2040) across all age groups. These plots show changes in prevalence relative to the baseline (no change in climate variables), highlighting those changes in future prevalence that can be attributed to the climate variables in the model. In these plots, we use a yellow and orange palette for the colored bands to illustrate the range of projected prevalence estimates under selected climate change scenarios. The concentration of orange in the fan indicates where the majority of these trajectories lie, representing the median, while the yellow areas depict the less likely trajectories. Appendix D shows the estimated absolute change in prevalence stratified by age group.

The second plot for each disease (3.2b, 3.3b, 3.4b, 3.5b) shows the projected percentage change in total aggregate deaths from the initial year (2024) to the final year (2040) across all age groups. This plot includes deaths due to the specific disease being modeled and other cause mortality. In these plots, we use a blue and violet palette for the colored bands to illustrate the range of projected total deaths under selected climate change scenarios. The concentration of violet in the fan indicates where the majority of these trajectories lie, representing the median, while the blue areas depict the less likely trajectories. Appendix D shows the estimated percentage change in total aggregate deaths stratified by age group.

In each of these two sets of figures (Figures 3.2a, 3.2b, 3.3a, 3.3b, 3.4a, 3.4b, 3.5a, and 3.5b), the lines represent seven specific case runs of the model dynamics. We made the choice to select seven case runs at random. The seven lines are not indicative of climate scenarios but rather serve as illustrative examples of individual trajectories. The close agreement between the lines and the bands is a feature of the deterministic model used, though this is not always the case.

The third plot (3.2c, 3.3c, 3.4c, 3.5c) is a box plot showing the percentage change in demand for the specific drug associated with each disease in the final year (2040) relative to the baseline (2024) scenario demand across all age groups. Each boxplot shows the distribution of demand estimates generated across the 100 model runs for each climate scenario.

### Climate Change and Demand for Metoprolol

Figures 3.2a–3.2c present the results of the CVD/metoprolol model. Aggregated across all age groups (Figure 3.2a), overall prevalence is estimated to be slightly lower than in the baseline scenario. This is driven by increased disease-specific and general mortality under climate change scenarios, as shown in Figure 3.2b. Overall, these changes in prevalence and mortality result in an estimated decrease in demand for metoprolol by 0.4 percent to 0.9 percent (Figure 3.2c).

Figure 3.2a Results of Cardiovascular Disease/Metoprolol Model: Projected Percentage Change in CVD Prevalence Compared to Baseline Under All Climate Change Scenarios and All Age Groups, 2024–2040

NOTE: Yellow and orange areas = range of projected prevalence estimates under selected climate scenarios; orange = more likely trajectory, yellow = less likely trajectory. Blue lines = randomly selected model runs.

Figure 3.2a depicts percentage change in cardiovascular disease prevalence relative to the baseline with the range of variations. The plot encompasses all climate change scenarios across all age groups. The baseline scenario is represented by a line at y equals 0. At the aggregated age-group level, overall cardiovascular disease prevalence shows a slight decrease with a median decrease from baseline of about 0.7 percent with a range of about 0.1 percent to about negative 2.0 percent.

Figure 3.2b Results of Cardiovascular Disease/Metoprolol Model: Projected Percentage Change in Total Deaths Compared to Baseline Under All Climate Change Scenarios and All Age Groups, 2024–2040

NOTE: Blue and violet areas = range of projected total deaths under selected climate scenarios; violet = more likely trajectory, blue = less likely trajectory. Blue lines = randomly selected model runs.

Figure 3.2b displays the percentage change in total aggregate deaths due to cardiovascular disease and other causes, starting from 2024. The plot illustrates the range of changes under different climate change scenarios, including the median and less likely projections. The baseline scenario is shown by a line at y equals 0. The mediate percentage change in aggregate deaths is about 2.0 percent with a range between 0.0 percent and over 5.0 percent

Figure 3.2c Results of Cardiovascular Disease/Metoprolol Model: Predicted Percentage Change in Demand for Metoprolol (2040)

Figure 3.2c shows box plots for the percentage change in demand for metoprolol in 2040, across five climate change scenarios, relative to the baseline scenario for 2040 across all age groups. This plot illustrates the range of medication demand across different climate change scenarios, with each box reflecting the progression from very low to very high climate change impacts. It is important to note that the demand varies significantly across age groups. At the aggregated age-group level, the overall demand decreases by 0.5 percent to 1 percent.

Analyzing the CVD model by age group results reveals nuanced impacts across different age groups under various climate change scenarios (Appendix D). Under the baseline scenario, CVD prevalence is projected to moderately increase for the three younger age groups (ages 20–64 years), with the trend stabilizing around 2035. In climate change scenarios, this increase becomes slightly more pronounced, as extreme weather events affect incidence rates more than mortality rates. For the three older age groups (ages 65 and above), baseline projections indicate a significantly greater increase in CVD prevalence, likely due to the aging population. Initially, under climate change scenarios, the rise in incidence rates is counterbalanced by higher mortality rates. However, in the oldest age group (85+), the increase in mortality rates eventually outweighs the rise in incidence rates. Changes in estimated demand for metoprolol by age group would be expected to mirror the changes in prevalence.

### Climate Change and Demand for Albuterol

Figures 3.3a–3.3c present the results of the asthma/albuterol model. Aggregated across all age groups (Figure 3.3a), overall asthma prevalence is estimated to increase relative to the baseline scenario. Similarly, aggregate deaths from asthma and other causes are expected to rise under all climate change scenarios, driven by increased disease-specific and general mortality (Figure 3.3b). Overall, these changes in prevalence and mortality result in an estimated increase in demand for albuterol by 1.5 percent to 3 percent (Figure 3.3c).

Figure 3.3a Results of Asthma/Albuterol Model: Projected Percentage Change in Asthma Prevalence Compared to Baseline Under All Climate Change Scenarios and All Age Groups, 2024–2040

NOTE: Yellow and orange areas = range of projected prevalence estimates under selected climate scenarios; orange = more likely trajectory, yellow = less likely trajectory. Blue lines = randomly selected model runs.

Figure 3.3a shows the percentage change in asthma prevalence relative to the baseline, including the range of variations. The plot encompasses all climate change scenarios across all age groups. The baseline scenario is represented by a line at y equals 0. Median relative changes and less probable variations are presented. At the aggregated age-group level, overall asthma disease prevalence shows a median increase from baseline of about 2.0 percent with a range between 0.0 percent and under 8.0 percent.

Figure 3.3b Results of Asthma/Albuterol Model: Projected Percentage Change in Total Deaths Compared to Baseline Under All Climate Change Scenarios and All Age Groups, 2024–2040

NOTE: Blue and violet areas = range of projected total deaths under selected climate scenarios; violet = more likely trajectory, blue = less likely trajectory. Blue lines = randomly selected model runs.

Figure 3.3b displays the percentage change in total aggregate deaths due to asthma and other causes, starting from 2024. The plot shows the range of changes under different climate change scenarios, including median projections, and less likely outcomes. The baseline scenario is shown by line at y equals 0. At the aggregated age-group level, total deaths increase under all climate change scenarios compared to baseline. The median increase is about 2.5 percent with a range from 0.0 percent to about 6.75 percent.

Figure 3.3c Results of Asthma/Albuterol Model: Predicted Percentage Change in Demand for Albuterol Across All Age Groups (2040)

Figure 3.3c, shows box plots for the percentage change in demand for albuterol in 2040, across the five climate change scenarios, relative to the baseline scenario for 2040 across all age groups. At the aggregated age-group level, overall demand is projected to increase by 1.5 percent in the “Very Low” climate change scenario and by up to 3 percent in the “Very High” climate change scenario.

As Figure D.2 in Appendix D shows, the impact of climate change on asthma prevalence varies by age group. In younger age groups (ages 0 to 4 and 5 to 14 years), the relative decrease or stabilization in asthma prevalence seen under the baseline scenario (without climate change) is disrupted. Climate change may prevent these decreases, potentially maintaining or even increasing prevalence in these age groups. In the 15 to 24 year age group, where prevalence peaks in the baseline scenario, climate change could prolong or intensify these peaks. For individuals aged 25 years and older, climate change is projected to significantly increase asthma prevalence, surpassing baseline expectations due to both exacerbation effects and demographic shifts. In contrast, for the older age group (65+ years), climate change may lead to a decrease in asthma prevalence, primarily due to increased mortality rates. Changes in demand for albuterol by age group would be expected to mirror the changes in prevalence.

### Climate Change and Demand for Heparin

Figures 3.4a–3.4c present the results of the ESRD/heparin model. Aggregated across all age groups (Figure 3.4a), overall prevalence is estimated to increase relative to the baseline scenario. Aggregate deaths from ESRD and other causes are expected to rise under all climate change scenarios, driven by increased disease-specific and general mortality (Figure 3.4b). Overall, these changes in prevalence and mortality result in an estimated increase in demand for heparin by 4.4 percent to 8.5 percent (Figure 3.4c).

Figure 3.4a Results of End-Stage Renal Disease/Heparin Model: Projected Percentage Change in ESRD Prevalence Compared to Baseline Under All Climate Change Scenarios and All Age Groups, 2024–2040

NOTE: Yellow and orange areas = range of projected prevalence estimates under selected climate scenarios; orange = more likely trajectory, yellow = less likely trajectory. Blue lines = randomly selected model runs.

Figure 3.4a presents the percentage change in end-stage renal disease prevalence relative to the baseline, including the range of variations. The plot encompasses all climate change scenarios across all age groups. The baseline scenario is represented by a line at y equals 0. Median relative changes and less probable variations are represented. At the aggregated age-group level, overall end-stage renal disease prevalence shows a median increase from baseline of about 5.5 percent with a range between 0.0 percent and over 17.5 percent.

Figure 3.4b Results of End-Stage Renal Disease/Heparin Model: Projected Percentage Change in Total Deaths Compared to Baseline Under All Climate Change Scenarios, 2024–2040

NOTE: Blue and violet areas = range of projected total deaths under selected climate scenarios; violet = more likely trajectory, blue = less likely trajectory. Blue lines = randomly selected model runs.

Figure 3.4b displays the percentage change in total aggregate deaths due to end-stage renal disease and other causes, starting from 2024 across all age groups. The plot illustrates the range of changes under different climate change scenarios, including median projections and less likely outcomes. The baseline scenario is shown by a line at y equals 0. The median percentage change in aggregate deaths is about 2.5 percent with a range between 0.0 percent and about 5.9 percent

Figure 3.4c Results of End-Stage Renal Disease/Heparin Model: Predicted Percentage Change in Demand for Heparin Across All Age Groups (2040)

Figure 3.4c shows box plots for the percentage change in demand for heparin in 2040, across five climate change scenarios, relative to the baseline scenario for 2040 across all age groups. At the aggregated age-group level, overall demand is projected to rise by 4.4 percent in the “Very Low” climate change scenario and up to 8.5 percent in the “Very High” climate change scenario.

Under the baseline scenario, ESRD is expected to increase in prevalence across all age groups, particularly among individuals over the age of 45 years (Appendix D, Figure D.3). Climate change amplifies this trend, maintaining higher prevalence rates even in the face of increased mortality due to climate impacts. Unlike CVD, the incidence rate of ESRD has been rising, which contributes to sustained and exacerbated prevalence under climate change scenarios. Changes in estimated demand for heparin by age group would be expected to mirror the changes in prevalence.

### Climate Change and Demand for Donepezil

Figures 3.5a–3.5c present the results of the Alzheimer’s/donepezil model. Aggregated across all age groups (Figure 3.5a), overall prevalence is expected to increase relative to the baseline scenario. Aggregate deaths from Alzheimer’s and other causes are expected to rise under all climate change scenarios, driven by increased disease-specific and general mortality (Figure 3.5b). Due to the substantial increase in Alzheimer’s disease prevalence, the demand for donepezil is expected to rise significantly, especially under climate change scenarios (Figure 3.5c). Overall demand for donepezil is projected to increase by 17.5 percent to 33.1 percent compared to baseline increases.

Figure 3.5a Results for Alzheimer’s Disease/Donepezil Model: Projected Percentage Change in Alzheimer’s Disease Prevalence Compared to Baseline Under All Climate Change Scenarios and All Age Groups, 2024–2040

NOTE: Yellow and orange areas = range of projected prevalence estimates under selected climate scenarios; orange = more likely trajectory, yellow = less likely trajectory. Blue lines = randomly selected model runs.

Figure 3.5a presents the percentage change in Alzheimer’s disease prevalence relative to the baseline, including the range of variations. The plot encompasses all climate change scenarios across all age groups. The baseline scenario is represented by a line at y equals 0. Median relative changes and less probable variations are depicted. The median percent increase in aggregate deaths is about 25.0 percent with a range between 0.0 percent and about 82.0 percent.

Figure 3.5b Results for Alzheimer’s Disease/Donepezil Model: Projected Percentage Change in Total Deaths Compared to Baseline Under All Climate Change Scenarios, 2024–2040

NOTE: Blue and violet areas = range of projected total deaths under selected climate scenarios; violet = more likely trajectory, blue = less likely trajectory. Blue lines = randomly selected model runs.

Figure 3.5b displays the percentage change in total aggregate deaths due to Alzheimer’s disease and other causes, starting from 2024 across all age groups. The plot illustrates the range of changes under different climate change scenarios, including median projections and less likely outcomes. The baseline scenario is shown by a line at y equals 0. The median increase in aggregate deaths is about 3.0 percent with a range between 0.0 percent and under 8.5 percent

Figure 3.5c Results for Alzheimer’s Disease/Donepezil Model: Predicted Percentage Change in Demand for Donepezil Across All Ages (2040)

Figure 3.5c shows box plots for the percentage change in demand for donepezil in 2040, across the five climate change scenarios, relative to the baseline scenario for 2040 across all age groups. The demand for donepezil is expected to rise significantly, especially under climate change scenarios. At the aggregated age-group level, overall demand for donepezil is projected to increase by 17.5 percent under the “Very Low” climate change scenario and up to 33.1 percent under the “Very High” climate change scenario, compared to baseline increases.

Our model for Alzheimer’s disease focused only on older age groups (55+ years). Prevalence and mortality are expected to increase among all age groups modeled (Appendix D, Figures D.4 and D.8).