# Chapter 2 Environmental Scan

We conducted reviews of peer-reviewed and grey literature to gather information required for developing a condition-specific systems dynamics model to estimate domestic future drug demand under climate change assumptions. In addition to identifying the list of medical conditions most likely to be affected by climate change, we identified the types of drugs that are most commonly used to treat the medical conditions. We paired the list of conditions with drugs that are among first-line treatments for each condition.

## Methods

### Peer-Reviewed and Grey Literature Search Strategies

Our search strategies (outlined in Appendix A) were structured by key concepts and combined to meet the different informational needs of the scan. Initially, we grouped chronic and acute health condition search terms using the International Classification of Diseases (ICD) standard classification of health categories (World Health Organization [WHO], undated). The search focused on the following types of health conditions: respiratory, cardiovascular, nephrological, allergies, malignant neoplasms, heat stress disorders, dermatologic, eye conditions, reproductive and maternal health, neurologic, mental health and psychiatric, and infectious (including vector-borne diseases).

Then we compiled climate change search terms, including meteorological events and factors relating to climate change such as air pollution. We developed a separate search strategy to identify existing climate models. This search combined the previous health and climate change terms with epidemiologic and statistical terms to inform the model.

Finally, the drug and pharmaceutical supply and demand terms combined specific drugs, both brand name and generic, and terms relating to demand and utilization.

A professional librarian searched the following electronic databases in April 2024: PubMed, Web of Science Core Collection (which consists of Science Citation Index Expanded [SCI-EXPANDED], Social Sciences Citation Index [SSCI], and Emerging Sources Citation Index [ESCI]), ESC Atlas of Cardiology, the Derwent Patents Citation Index (Clarivate), Scopus (Elsevier), Academic Search Complete (EBSCOhost), Military Database (ProQuest), and IEEE Xplore. We restricted the search strategy for health impacts and climate change to U.S. studies published in English between 2014 and 2024. To enable a broader knowledge of the modeling literature, we expanded the search to include international studies from 2000 to 2024. Expanding modeling literature to include international studies was important because the number of models that predict future prevalence of medical conditions in the United States (especially under climate scenarios) are limited. The librarian manually removed duplicates using EndNote’s duplicate identification strategy.

We adapted the above search for the grey literature review, which included the document repositories of the WHO, the Centers for Disease Control and Prevention (CDC), the U.S. Department of Health and Human Services (HHS), and the U.S. Environmental Protection Agency (EPA).

## Results

### Peer-Reviewed and Grey Literature Search Results

Our peer-reviewed search strategies yielded a total of 1,523 unique articles from the combined database results. After the initial screening of titles and abstracts, 80 articles advanced to the second level of screening (full-text review). Of these, 67 articles were deemed relevant for report inclusion and further analysis. Our grey literature search strategies yielded a total of 122 unique articles. After the initial screening of titles and abstracts, 103 articles advanced to the second level of screening (full-text review). Of these, 41 articles were deemed relevant for report inclusion and further analysis. Among the studies that underwent full-article review, the research designs were primarily observational. These observational studies varied in the types of the methods used and included case-crossover, time series, health impact assessment, ecological, cross-sectional, surveillance, cohort, case control designs, review articles, and modeling studies.

### Climate Threats and Health

Climate change presents significant health threats to human populations around the globe. Increasing atmospheric carbon dioxide and other greenhouse gases are driving an increase in the earth’s temperature. These climatologic factors affect the prevalence of both acute illnesses, such as infectious diseases, and chronic diseases through the effects of temperature, humidity, and other weather-related phenomena on pathogens, vectors, animal hosts, land use, and migration (Edelson et al., 2023). Both hot and cold temperature extremes have been associated with increased morbidity and mortality (Gasparrini et al., 2015; Gronlund et al., 2018). Recent longer and more-severe heatwaves have proven to be especially fatal (DHHS, undated). Thunderstorm-related atmospheric changes can trigger acute respiratory illnesses and are anticipated to become more frequent as temperatures rise. Drought and high winds can circulate increased levels of particulate matter, such as PM2.5 (particles that are 2.5 microns or less in diameter that can travel deep into the respiratory tract), leading to respiratory illness and increased all-cause mortality (Abadi et al., 2022; Sun et al., 2015). Particulate matter, which can be a component of air pollution and wildfires, has been associated with higher atmospheric concentrations of carbon dioxide, which can lead to increased pollen production and a prolonged pollen season.

Climate change has been identified as a major contributor to the increasing frequency and size of wildfires, and it has also been shown to exacerbate flood risks in U.S. coastal regions that pose various risks to human health (National Oceanic and Atmospheric Administration, National Centers for Environmental Information [NOAA], 2023), such as exposure to waterborne pathogens (Levy, Smith, and Carlton, 2018). Furthermore, climate change has been associated with a rise in surface ozone levels that, in turn, have been associated with increased mortality (Sun et al., 2015; Alexeeff, Pfister, and Nychka, 2016).

The extent to which extreme weather risks affect human health may be determined by the nature of the physical hazards, such as heat and wind; the extent of a population’s exposure to the hazard; the vulnerability of the population; and the resiliency of the affected community. Regardless of the type of weather event, all types of extreme weather can result in infrastructure and/or societal disruption. Furthermore, extreme weather events can result in extremely high economic costs to the United States. As of July 2024, the cost of weather-related disasters in the United States has already reached $37.9 billion in 2024 alone (NOAA, National Centers for Environmental Information, 2024).

### Climate-Vulnerable Health Conditions in the United States

A number of health conditions are particularly vulnerable to the effects of climate change—although the mechanisms for these vulnerabilities are not always well understood. Climate change is expected to increase the prevalence of these conditions, and people with these conditions are more susceptible to climate change’s adverse effects. Below, we discuss examples of those conditions for which there is evidence for negative impact from climate change as reported in U.S.-based studies. Given differences in population demographics and disease prevalence in other countries compared to the United States, we base the discussion of the effect of climate-vulnerable conditions in the United States exclusively on U.S.-based studies.

#### Cardiopulmonary Disease

Heat, wildfire smoke, air pollution, and elevated ozone levels can all exacerbate cardiopulmonary stress. Extreme temperatures have been associated with increased risk of various cardiovascular conditions, such as myocardial infarction (i.e., heart attacks) (Rowland et al., 2020), and increased risk of adverse outcomes for stroke and other cardiovascular diseases (CVDs) (Mazidi and Speakman, 2020). Several direct and indirect mechanisms are responsible for these effects. Higher temperatures lead to higher surface blood circulation and sweating, both of which contribute to higher levels of strain on the heart. Furthermore, high temperatures may lead to sleep disturbances and decreased physical activity, both of which increase the risk of CVD. Both high and low temperatures have been reported to increase risk of coagulopathy (i.e., clot formation), which can facilitate cardiovascular events (Levi, 2018).

Increased levels of air pollution are linked to higher risk of acute coronary syndrome, peripheral artery disease, cardiac arrhythmia, and heart failure (Rowland et al., 2019, Mazidi and Speakman, 2020). Climate change also amplifies the adverse health effects of diabetes (a risk factor for CVD) (Al-Shihabi, Moore, and Chowdhury 2023). For example, a Commonwealth of Virginia–based study showed an association between cold weather and increased diabetes-related emergency department (ED) visits (Davis, Driskill, and Novicoff, 2022).

Wildfire smoke is associated with poor respiratory outcomes as well, such as decreased lung function among people with and without preexisting asthma (Wilgus and Merchant, 2024). Exposure to extreme heat and precipitation events is associated with increased asthma-related hospitalizations (Soneja et al., 2016). Furthermore, dust outbreaks that worsen particulate matter air pollution have been associated with chronic obstructive pulmonary disease (COPD) exacerbations (Gutierrez et al., 2020).

#### Kidney Disease

The prevalence of chronic kidney disease (CKD) has increased over the past two decades (Kovesdy, 2022), especially in areas with chronic heat stress and air pollution. Dehydration secondary to heat stress is one mechanism that can worsen poor kidney function. A study of 2 million U.S. veterans found that exposure to increased PM2.5 and gaseous pollutants, in addition to exacerbating many of the risk factors associated with kidney disease, such as hypertension and diabetes, led to the progression of CKD and renal failure (Rasking et al., 2022). One hypothesis to explain this effect is that particulate matter entering the bloodstream can result in pathological changes in the kidneys (Tavera Busso et al., 2018). Among patients with CKD, extreme heat has been associated with increased hospitalizations and mortality (Remigio et al., 2019).

#### Mental Health and Neurological Diseases

Climate-related events such as wildfires have been associated with increased risk for mental health conditions (Clayton, 2021), such as major depressive disorder, posttraumatic stress disorder, and generalized anxiety disorder (Wettstein and Vaidyanathan, 2024; Monsour et al., 2022).

Exposure to heat stress in an animal model study was associated with “misfolding” of brain proteins—a process by which the shape of a protein changes—causing protein aggregation. In the context of heat exposure, one can postulate that similar processes in humans may lead to increasing prevalence of Alzheimer’s disease (Bongioanni et al., 2021). Individuals with neurological disorders such as Alzheimer’s disease are also at increased risk of health complications due to extreme heat largely because of an inability to take steps to protect themselves from heat exposure. Furthermore, extreme heat can result in dehydration and increase the risk of infection and kidney disease in this population (Stella et al., 2023). Concerns have been raised for similar risks from heat waves among individuals with other neurodegenerative diseases, such as Parkinson’s disease and motor neuron diseases (Bongioanni et al., 2021).

#### Infectious Diseases

Lyme disease, a tick-borne disease and the most common vector-borne illness in the United States, has been found to have earlier annual disease onset (Monaghan et al., 2015), and warmer temperatures have been reported to contribute to the expanding habitat of the Lyme-carrying tick putting more people at risk. Past outbreaks of West Nile Virus, another vector-borne infectious disease, have been attributed to stagnant water reservoirs and elevated temperatures in the context of drought (Limaye et al., 2019).

Exposure to storm-related flooding has been associated with a rise in Shiga toxin-producing Escherichia coli (E. coli) infections and an increase in Legionnaires’ disease and cases of cryptosporidiosis (Lynch and Shaman, 2023). Prior research has shown an association between extreme precipitation and waterborne diseases such as Salmonellosis (Morgado et al., 2021) and Vibrio vulnificus infections (Archer et al., 2023). One study demonstrated a potential association between climate-mediated flooding and Clostridium difficile infections (Lin, Wade, and Hilborn, 2015).

Fungal infections have also been reported to be on the rise as a result of climate change. For example, rising heat and moisture may be creating ideal conditions for the growth of the Coccidioides fungus—the organism responsible for Valley Fever—and contributing to an increased incidence of infections in previously unaffected regions (Gorris et al., 2019). Valley Fever outbreaks may be associated with severe dust storms that increase dust concentrations and disperse the fungus.

#### Maternal-Fetal Health

Heat exposure throughout pregnancy puts women at risk of heat illness and heat stroke (CDC, undated-b). Exposure to temperature extremes increases the risk of cardiovascular complications for pregnant women during labor and delivery (Ha et al., 2017). Extreme temperatures have also been associated with an increased risk of poor fetal growth (Sun et al., 2019) and stillbirths (Ha et al., 2017).

#### Cancer

Existing literature raises concerns about a potential link between a warming planet and increased incidence of skin cancer (Parker, 2021). Furthermore, wildfires have been reported to increase the concentration of hazardous air pollutants—chemicals that are known or suspected carcinogens (Rice et al., 2023; Tee Lewis et al., 2023).

### Climate-Vulnerable Populations and Locations

The effects of climate-related weather events are widespread and certain populations and locations are particularly vulnerable to their impacts (Tee Lewis et al., 2023; Zhang et al., 2019). Children (Leffers, 2022), pregnant women (Ha et al., 2017), and older adults (Carnes, Staats, and Willcox, 2014) are particularly vulnerable to the health effects of climate change. Overall, climate change disproportionately affects the health status of people of color because of socioeconomic inequities (Flores et al., 2020) and health care disparities (Berberian, Gonzalez, and Cushing, 2022; Guirguis et al., 2018). In the context of climate change, these vulnerable populations are at greater risk because of higher exposure to climate threats and lack of ability and/or resources to prepare, adapt, and recover from climate-related extreme weather events (Tee Lewis et al., 2023).

Depending on the specific geographic region in the United States, the nature and severity of climate threats vary. Furthermore, certain localities may be at higher risk. An important example is extreme heat in urban centers, which is a major environmental health stressor. Urban heat events are those above the 90th percentile of historical temperatures for a given location and are exacerbated by the “urban heat island” phenomenon (Howard, 2012; Debbage and Shepherd, 2015). The urban heat island refers to the strong correlation between urban environments and high temperatures stemming from impermeable urban surfaces, human activity, and the relative paucity of green environments (such as grass and trees) to mitigate rising temperatures. Furthermore, risk of extreme precipitation (for example, in the setting of hurricanes) is variable across the United States, with coastal areas being at highest risk (Federal Emergency Management Agency, undated).

### Climate Effects on Demand for Health Services and Drugs

Severe weather events can also disrupt health systems and access to services—for example, through surges in patient volumes or impeded physical access to health facilities (Flores et al., 2020). Delayed access to health services and needed drugs can result in acute exacerbation of chronic conditions, such as asthma, diabetes, and congestive heart failure, leading to a need for ED services or hospitalization. A study of 42 large disasters in the United States found an increase in ED visits among Medicare beneficiaries in the week following the event in affected counties (Salas et al., 2024).

### Climate Effects on Medical Supply Chains

Medical supply chains are sensitive to disruptions, such as those resulting from natural disasters. After a natural disaster, there is a surge in disease burden and demand for related drugs, making timely access to health care facilities and medical treatment critical. Furthermore, extreme weather-related events can interrupt manufacturing and/or delivery of medical supplies to end users. Increased demand for drugs and challenges with insufficient supplies in the context of extreme weather climate events can affect access to time-sensitive treatments.

According to the U.S. Food and Drug Administration (FDA), about a quarter of drug shortages in the United States in 2023 were due to increased drug demand (FDA, 2024). Other reasons for drug shortages in that year included delays in shipment, active ingredient shortages, and manufacturers not complying with practice standards. Currently, the FDA does not have the authority to require manufacturers to report shortages that are likely due to increases in demand for drugs, making mitigating drug shortages more challenging.

Increased demand in the context of climate-related events can compound existing drug shortages (Kolbe and Beleche, 2024; NASEM, 2022). Such shortages may be exacerbated during, or even as a result of, public health emergencies (for example, during the coronavirus disease 2019 [COVID-19] pandemic and in the aftermath of Hurricane Maria). Extreme weather events may hinder production of drugs and/or the “last mile” delivery of the products to end users (Kolbe and Beleche, 2024; NASEM, undated; NASEM, 2022).