# Chapter 1 Objective and Approach

## Objective

Climate change is increasing the frequency and intensity of extreme weather events and related disasters. Past studies have linked extreme weather events—including extreme hot and cold weather—to poor health outcomes and increased demand for health services and drugs used to treat conditions that are predicted to become more prevalent with a changing climate (Salas et al., 2024). At the same time, drug shortages have been an ongoing public health concern for decades and could become more so with the increase in climate-related demand. The U.S. government and the private sector—including suppliers, manufacturers, distributors, wholesalers, and providers—need a better understanding of how climate change could affect disease burden and the demand for drugs. Such information can support advance planning to strengthen medical supply chain resiliency.

We attempted to shed light on these issues by (1) estimating the degree to which disease burden will increase in a sample of medical conditions likely to be affected by climate change and (2) modeling future demand for a sample of drugs used to treat the sampled conditions.

## Overview of Approach

We started by conducting an environmental scan of peer-reviewed and grey literature focused on the following topics:

1. the conditions most likely to be affected by climate change and their prevalence
2. the most common drugs, biologics, and/or medical devices needed to treat those conditions and their baseline (i.e., current) demand
3. any supply chain shortages experienced by these commonly used drugs
4. models estimating future increases in disease prevalence as a result of climate change.

This scan helped determine the final sample of four conditions and drugs (one to treat each of these conditions). The information gleaned from the above steps served as inputs for a medical condition–specific systems dynamics model that we developed to predict demand for those drugs in the context of various climate change scenarios (described in Chapter 3). The model estimated demand for each drug under various assumptions for climate impact.

## Organization of This Report

The remainder of this report consists of three chapters and four appendixes. In Chapter 2, we present the methods and results for the environmental scan. In Chapter 3, we outline the methods and results for the systems dynamics model. In Chapter 4, we discuss the study findings and future directions. We provide further details of our methods and analysis in the appendixes.