# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
BMI: body mass index
CDC: Centers for Disease Control and Prevention
CKD: chronic kidney disease
COPD: chronic obstructive pulmonary disease
COVID-19: coronavirus disease 2019
CVD: cardiovascular disease
ED: emergency department
EPA: Environmental Protection Agency
ESRD: end-stage renal disease
FDA: Food and Drug Administration
GHG: greenhouse gases
HHS: U.S. Department of Health and Human Services
ICD: International Classification of Diseases
IPCC: Intergovernmental Panel for Climate Change
ODE: ordinary differential equations
PM2.5: particulate matter 2.5
ppb: parts per billion
RRT: renal replacement therapy
SSP: Shared Socioeconomic Pathway
WHO: World Health Organization