# Appendix D Projected Prevalences and Percentage Changes in Deaths by Age Group for Each Condition

Figures D.1–D.4 show the projected prevalence from the initial year (2024) to the final year (2040) for each of the four sampled medical conditions, with each age group displayed in separate panels. The baseline prevalence trajectory is represented by a bold black line, indicating how the prevalence of each disease would change over time without the influence of climate change effects. The pink and purple bands illustrate the range of projected prevalence trajectories under the modeled climate change scenarios, from least severe to most severe. These scenarios incorporate varying inputs within their uncertainty ranges, describing how extreme weather events, influenced by climate change, affect incidence and mortality rates. The concentration of purple in the fan indicates where the median of these trajectories lies, and the pink areas depict the less likely trajectories.

Figure D.1 CVD Prevalence Projections Compared to Baseline Under All Climate Change Scenarios by Age Group, 2024–2040

NOTE: Pink and purple areas = range of projected prevalence estimates under selected climate scenarios; purple = more likely trajectory, pink = less likely trajectory. Bold black line = baseline scenario; blue lines = randomly selected model runs.

Figure D.1 shows the projected cardiovascular disease prevalence from the initial year (2024) to the final year (2040) for cardiovascular disease for the following age groups: 20 to 34, 35 to 49, 50 to 64, 65 to 74, 75 to 84, 85 plus. Under the baseline scenario, cardiovascular disease prevalence is projected to moderately increase for the three younger age groups ages 20-64 with the trend stabilizing around 2035. In climate change scenarios, this increase becomes slightly more pronounced. For the three older age groups ages 65 and above baseline projections indicate a significantly greater increase in cardiovascular disease prevalence.

Figure D.2 Asthma Prevalence Projections Compared to Baseline Under All Climate Change Scenarios by Age Group, 2024–2040

NOTE: Pink and purple areas = range of projected prevalence estimates under selected climate scenarios; purple = more likely trajectory, pink = less likely trajectory. Bold black line = baseline scenario; blue lines = randomly selected model runs.

Figure D.2 shows the projected asthma prevalence from the initial year (2024) to the final year (2040) for the following age groups: 0 to 4, 5 to 14, 15 to 19, 20 to 24, 25 to 34, 35 to 49, 35 to 64, and 65 plus. The baseline scenario projects an increase in asthma prevalence. The impact of climate change varies by age group. In younger age groups ages 0 to 4 and 5 to 14, the relative decrease or stabilization in prevalence seen under the baseline scenario without climate change is disrupted. In the 15 to 19 and 20 to 24 age groups, where prevalence peaks in the baseline scenario, climate change could prolong or intensify these peaks. For individuals aged 25 and older, climate change is projected to significantly increase asthma prevalence, surpassing baseline expectations. Among the 65 plus age group, climate change may lead to a decrease in prevalence.

Figure D.3 End-Stage Renal Disease Prevalence Projections Compared to Baseline Under All Climate Change Scenarios by Age Group, 2024–2040

NOTE: Pink and purple areas = range of projected prevalence estimates under selected climate scenarios; purple = more likely trajectory, pink = less likely trajectory. Bold black line = baseline scenario; blue lines = randomly selected model runs.

Figure D.3 shows the projected end-stage renal disease prevalence from the initial year 2024 to the final year 2040 for the following age groups: 0 to 17, 18 to 44, 45 to 64, 65 to 74, and 75 plus. The baseline trajectory and the climate change scenarios along with their associated uncertainties are depicted. Median and less likely trajectories are shown. End-stage renal disease baseline trends show increasing prevalence across all age groups, especially for those over the age of 45. Climate change intensifies this higher prevalence trend.

Figure D.4 Alzheimer’s Disease Prevalence Projections Compared to Baseline Under All Climate Change Scenarios by Age Group, 2024–2040

NOTE: Pink and purple areas = range of projected prevalence estimates under selected climate scenarios; purple = more likely trajectory, pink = less likely trajectory. Bold black line = baseline scenario; blue lines = randomly selected model runs.

Figure D.4 shows the projected Alzheimer’s Disease prevalence from the initial year (2024) to the final year (2040) for the following age groups: 55 to 64, 65 to 74, 75 to 84, and 85 plus. The baseline trajectory and the climate change scenarios, along with their associated uncertainties, are represented. Median prevalence projections, whereas lighter pink areas show less likely trajectories. Alzheimer’s disease shows relatively stable prevalence trends for those aged 55 to 74 in the baseline scenario. However, climate change is projected to increase prevalence by 20 percent to 30 percent for this age group. For older age groups 75 to 84 and 85 plus, the baseline scenario anticipates a significant increase in Alzheimer's disease prevalence, especially for those aged 85 and older. Climate change exacerbates this increase.

Figures D.5–D.7 show projected percentage change in total deaths compared to the baseline scenarios under all climate change scenarios by age group from 2024 to 2040 for each of the conditions modeled.

Figure D.5 Results of Cardiovascular Disease/Metoprolol Model: Projected Percentage Change in Total Deaths Compared to Baseline Under All Climate Change Scenarios by Age Group, 2024–2040

NOTE: Blue and violet areas = range of projected total deaths under selected climate scenarios; violet = more likely trajectory, blue = less likely trajectory. Blue lines = randomly selected model runs.

Figure D.5 related to the cardiovascular disease model shows projected percentage change in total deaths compared to baseline under all climate change scenarios from 2024 to 2040 for the following age groups: 20 to 34, 35 to 49, 50 to 64, 65 to 74, 75 to 84, and 85 plus. Cardiovascular disease mortality increases among all the above age groups. Among the 20 to 34 age group the median increase from baseline is 2.0 percent with a range from 0 percent to 6.0 percent. For the 35 to 49 age group, the median increase from baseline is about 3.0 percent with a range from 0 percent to over 6.0 percent. Among the 50 to 64 age group the median increase from baseline is about 2.0 percent with a range from 0 percent to 6.0 percent. Among the 65 to 74 age group, the median increase from baseline is about 3.0 percent with a range from 0 percent to over 6.0 percent. Among the 75 to 84 age group the median increase from baseline is about 3.0 percent with a range from 0 percent to 6.0 percent. For the 85 plus age group, the median increase from baseline is about 1.5 percent with a range from 0 percent to over 4.0 percent.

Figure D.6 Results of Asthma/Albuterol Model: Projected Percentage Change in Total Deaths Compared to Baseline Under All Climate Change Scenarios by Age Group, 2024–2040

NOTE: Blue and violet areas = range of projected total deaths under selected climate scenarios; violet = more likely trajectory, blue = less likely trajectory. Blue lines = randomly selected model runs.

Figures D.6 related to the asthma model shows projected percentage change in total deaths compared to baseline under all climate change scenarios from 2024 to 2040 for the following age groups: 0 to 4, 5 to 14, 15 to 19, 20 to 24, 25 to 34, 35 to 49, 35 to 64, and 65 plus. Asthma mortality increases among all the above age groups. Among the 0 to 4 age group the median increase from baseline is about 3.0 percent with a range from 0 percent to over 6.5 percent. For the 5 to 14 age group, the median increase from baseline is about 3.0 percent with a range from 0 percent to over 6.5 percent. Among the 15 to 19 age group the median increase from baseline is about 2.5 percent with a range from 0 percent to over 6.5 percent. Among the 20 to 24 age group the median increase from baseline is about 3.0 percent with a range from 0 percent to over 6.5 percent. Among the 25 to 34 age group the median increase from baseline is about 3.0 percent with a range from 0 percent to over 6.5 percent. Among the 35 to 64 age group the median increase from baseline is about 3.0 percent with a range from 0 percent to over 6.5 percent. Among the 65 plus age group the median is about 2.5 percent with a range from 0 percent to about 6.5 percent.

Figure D.7 Results of End-Stage Renal Disease/Heparin Model: Projected Percentage Change in Total Deaths Compared to Baseline Under All Climate Change Scenarios by Age Group, 2024–2040

NOTE: Blue and violet areas = range of projected total deaths under selected climate scenarios; violet = more likely trajectory, blue = less likely trajectory. Blue lines = randomly selected model runs.

Figure D.7 related to the end-stage renal disease model shows projected percentage change in total deaths compared to baseline under all climate change scenarios for 2024 to 2040 for the following age groups: 0 to 17, 18 to 44, 45 to 64, 65 to 74, and 75 plus. End-stage renal disease mortality increases among all the above age groups. Among the 0 to 17 age group the median increase from baseline is about 3.0 percent with a range from 0 percent to just under 7.0 percent. For the 18 to 44 age group, the median increase from baseline is about 3.0 percent with a range from 0 percent to 6.5 percent. Among the 45 to 64 age group the median increase from baseline is about 3.0 percent with a range from 0 percent to about 6.5 percent. Among the 65 to 74 age group the median increase from baseline is about 2.0 percent with a range from 0 percent to over 6.0 percent. Among the 75 plus age group the median increase from baseline is about 3.0 percent with a range from 0 percent to about 6.5 percent.

Figure D.8 Results of Alzheimer’s/Donepezil Model: Projected Percentage Change in Total Deaths Compared to Baseline Under All Climate Change Scenarios by Age Group, 2024–2040

NOTE: Blue and violet areas = range of projected total deaths under selected climate scenarios; violet = more likely trajectory, blue = less likely trajectory. Blue lines = randomly selected model runs.

Figure D.8 related to the Alzheimer’s model shows projected percentage change in total deaths compared to baseline under all climate change scenarios from 2024 to 2040 for the following age groups: 55 to 64, 65 to 74, 75 to 84, and 85 plus. Alzheimer’s mortality increases among all the above age groups. Among the 55 to 64 age group the median increase from baseline is about 3.0 percent with a range from 0 percent to about 8.0 percent. For the 65 to 74 age group, the median increase from baseline is about 3.0 percent with a range from 0 percent to over 8.0 percent. Among the 75 to 84 age group the median increase from baseline is about 4.0 percent with a range from 0 percent to about 10.0 percent. Among the 85 plus age group the median increase from baseline is about 3.0 percent with a range from 0 percent to over 7.0 percent.