# Appendix C Model Inputs and Transformations

The text below describes the sources, transformations, and assumptions for all the inputs to the model.

## Global Temperature Projections

No changes from source (Fyfe et al., 2021). Global temperature projections are drawn from five illustrative climate change scenarios. Emissions estimates vary between the scenarios depending on socio-economic assumptions, levels of climate change mitigation, and air pollution controls.

## Global Temperature Changes Projections Relative to 2024

Because our model treats 2024 as the baseline year, we converted the global temperature projections corresponding to each climate change scenario used in the model into a relative value to the 2024 temperature. We achieved this for each scenario by subtracting the temperature for 2024 from the temperature values for all subsequent years up to 2040.

## Temperature-Climate Links

Relationship between Global and U.S. temperatures: EPA (undated-c) provided temperature data dating back to 1901 for changes in U.S. and global mean temperatures relative to each of their respective long-term average temperatures. These two series were converted from Fahrenheit to degrees Celsius.

Following this conversion, we constructed a linear regression as follows with change in U.S. mean annual temperature as the outcome variable:

U S t e m p e r a t u r e c h a n g e = β_1_ ∗ G l o b a l t e m p e r a t u r e c h a n g e + i n t e r c e p t + e r r o r

The coefficient β_1_ represents the change in the mean annual U.S. temperature for a 1-degree Celsius increase in the mean annual global surface temperature.

U.S. temperature changes and extreme heat days: EPA (undated-a) provided decadal data for the average annual heatwave frequency, duration, season, and intensity. To get the average number of extreme heat days in a year, we used the following equation:

A v e r a g e a n n u a l e x t r e m e h e a t d a y s = A n n u a l h e a t w a v e f r e q u e n c y ∗ A n n u a l h e a t w a v e d u r a t i o n

Following this calculation, we constructed a linear regression as follows with the number of extreme heat days as the outcome variable:

N u m b e r o f a n n u a l e x t r e m e h e a t d a y s = β_2_ ∗ U S t e m p e r a t u r e c h a n g e + i n t e r c e p t + e r r o r

The coefficient β_2_ represents the change in the annual number of extreme heat days for a 1-degree Celsius increase in the mean annual U.S. temperature.

U.S. temperature changes and hurricanes: EPA (undated-b) provided data for the annual incidence of hurricanes that make landfall in the United States. We constructed a linear regression as follows with the number of hurricanes making landfall in the United States as the outcome variable:

N u m b e r o f h u r r i c a n e s m a k i n g l a n d f a l l i n t h e U n i t e d S t a t e s = β_3_ ∗ U S t e m p e r a t u r e c h a n g e + i n t e r c e p t + e r r o r

The coefficient β_3_ represents the change in the annual number of hurricanes making landfall in the United States for a 1 degree Celsius increase in the mean annual U.S. temperature.

U.S. temperature changes and air quality: Our chosen metrics for measuring air quality are the concentration of particulate matter (PM2.5) and ground-level ozone. However, when observing the raw temporal trends for these two pollutants, we observed an overall decline due to improving overall air quality in the recent past. Wildfires, which have a demonstrated link to climate change (U.S. Geological Survey, undated), are linked to increased emissions of particulate matter and ozone. Therefore, instead of directly relating temperature rise in the United States with PM2.5 and ozone, we related temperature increases with wildfire extent as a first step, and then related changes in wildfire extent to changes in the concentration of PM2.5 and ground-level ozone.

1. EPA (undated-e) provided annual data for wildfire extent in acres and we converted this series into millions of acres by dividing each datapoint by 1,000,000. Then we constructed a linear regression as follows with wildfire extent as the outcome variable:
  W i l d f i r e e x t e n t = β_4_ ∗ U S t e m p e r a t u r e c h a n g e + i n t e r c e p t + e r r o r
  The coefficient β_4_ represents the change in wildfire extent in millions of acres for a 1-degree Celsius increase in the mean annual U.S. temperature.
2. Next, we found a model (Burke et al., 2021) in the literature that suggested that 25 percent of PM2.5 emissions in 2020 were attributable to wildfires. We assumed that there is a linear relationship between wildfire extent and PM2.5 emissions, and thus divided EPA’s PM2.5 concentrations for 2020 (EPA, undated-f) by the wildfire extent in 2020 (in millions of acres), and then multiplied the results by 0.25 to estimate PM2.5 emissions produced per million acres burnt by wildfires. We divided the result by 10 to standardize the change in PM2.5 concentration to 10s of μg/m^3^ which are the units used between exposure to PM2.5 and all-cause mortality, disease mortality, and disease incidence. For simplicity, we assumed that the ratio of wildfire extent to PM2.5 emissions will remain stable and PM2.5 will change linearly as wildfire extent changes in response to climate change.
3. We found another model (Jaffe et al., 2008) in the literature that estimated an increase in ground-level ozone emissions by 2 parts per billion (ppb) for every million acres of wildfire extent. We divided this result here by 10 to standardize the units to 10s of ppb. We have assumed a static relationship between wildfire extent and ground-level ozone for simplicity.

## Baseline Medical Conditions

### Cardiovascular Disease

In alignment with the data sources, we used six input age groups for this model: 18–24, 25–44, 45–54, 55–64, 65–74, and 75+ years.

1. CVD mortality: To calculate the baseline mortality for CVD, we used data from the CDC’s WONDER system that tracks mortality statistics (CDC, undated-c). We filtered the data by cause of death corresponding to ICD Chapter I00-I00 codes (Diseases of the Circulatory System) and age. For age, we chose to filter by single-year age groups in order to standardize the age groups with the CVD prevalence data sourced from elsewhere. We then collated the data from single-year age groups to create larger age groups. For instance, the source returned the deaths and total population for individuals aged 18 years, 19 years, 20 years etc. We created the age group 18-24 by summing up the total deaths among the single age-groups between age 18 and age 24, summing the total population of the single-year age groups between age 18 and age 24, then divided the former by the latter and multiplied by 100,000 to get the average mortality rate for age group 18–24 in terms of deaths per 100,000 individuals. This process was repeated to create all the CVD mortality age groups. However, since the age groups created using these data did not necessarily line up with the age groups we were using in our model, we needed to interpolate and obtain mortality rates for our chosen groups. This was done by fitting our mortality rates as calculated from the CDC data to a polynomial. The dataset did not report population statistics for individuals 85 and older. Therefore, we applied the death rate for ages 75 to 84 to individuals aged 85+ years.
2. CVD incidence: We were unable to find data on CVD incidence, however historic prevalence data by age group shows that CVD prevalence has remained relatively stationary over the past decade. Based on this information, and assuming stationary demographic dynamics, we assumed that the deaths that deplete the CVD-diagnosed population would need to be balanced by the equivalent inflow of newly diagnosed (incident) CVD cases. Therefore, we chose to use CVD baseline mortality estimates as a proxy for CVD baseline incidence in the model.
3. CVD prevalence: We used self-reported prevalence data from the CDC (undated-e), which reported the prevalence of CVD for each age group in percentage of adults. The CDC data were not provided according to the same age groups as our model; therefore, we used a fourth-order polynomial fitting technique to adjust the CDC prevalence data to align with our age groups. We converted this series to cases per 100,000 individuals by multiplying each datapoint by 1,000.

### End-Stage Renal Disease

In alignment with the data sources, we used five input age groups for this model: 0–17, 18–44, 45–64, 65–74, and 75+ years.

1. ESRD mortality: For the baseline mortality of ESRD, we used the mortality rate in deaths per 1,000 person-years from the U.S. Renal Data System’s 2023 Annual Data Report (NIDDK, undated-a; NIDDK, 2023). Data from the U.S. Renal Data System were not provided according to the same age groups as our model; therefore, we used a fourth-order polynomial fitting technique on the logarithm of mortality rates to adjust the ESRD mortality data to align with our age groups. The report mentioned that the majority of patients were observed for a period of one year, so we assumed this mortality rate to be equivalent to deaths per 1,000 patients. We converted this estimate into individual deaths by dividing each mortality rate by 1,000, then multiplied the results by the corresponding prevalence of ESRD for each age group in cases per 100,000 individuals. Mortality data were unavailable for the 0–17 years age group.
2. ESRD incidence: For the baseline incidence of ESRD, we used incidence data from the U.S. Renal Data System’s 2023 Annual Data Report (NIDDK, undated-a; NIDDK, 2023). We converted this series to cases per 100,000 individuals by dividing each datapoint by 10 for each age group. Data from the U.S. Renal Data System were not provided according to the same age groups as our model; therefore, we used a fourthorder polynomial fitting technique to adjust the U.S. Renal Data System prevalence data to align with our age groups.
3. ESRD prevalence: For the baseline prevalence of ESRD, we used prevalence data from the U.S. Renal Data System’s 2023 Annual Data Report (NIDDK, undated-a; NIDDK, 2023). We converted this series to cases per 100,000 individuals by dividing each datapoint by 10 for each age group. Data from the U.S. Renal Data System were not provided according to the same age groups as our model; therefore, we used a fourthorder polynomial fitting technique to adjust the U.S. Renal Data System prevalence data to align with our age groups.

### Asthma

In alignment with the data sources, we used seven input age groups for this model: 0–4, 5–14, 15–19, 20–24, 25–34, 35–64, and 65+ years.

1. Asthma mortality: To calculate the baseline mortality for asthma, we used CDC underlying cause of death data (CDC, undated-c), for ICD-10 codes J45–J46 (asthma). We converted this series from the death rate per 1,000,000 individuals to deaths per 100,000 individuals by dividing each datapoint by 10.
  The age cutoffs differed between the prevalence and mortality data for the age groups 5–14, 15–19, and 20–24 years, and the age groups 5–11, 12–17, and 18–24 years, respectively. We assumed that these data would not differ significantly, therefore we used the age groups from the prevalence dataset for the mortality data in the model. The CDC data were not provided according to the same age groups as our model; therefore, we used a fourth-order polynomial fitting technique on the logarithm of mortality rates to adjust the asthma mortality data to align with our age groups.
2. Asthma incidence: We were unable to find data on asthma incidence, however historic prevalence data by age group show that asthma prevalence has remained relatively stationary over the past decade. Based on this information, and assuming stationary demographic dynamics, we assumed that the deaths that deplete the asthma-diagnosed population would need to be balanced by the equivalent inflow of newly diagnosed (incident) asthma cases. Therefore, we chose to use asthma baseline mortality estimates as a proxy for asthma baseline incidence in the model.
3. Asthma prevalence: To calculate baseline prevalence of asthma, we used self-reported prevalence data from the CDC (CDC, undated-d) for each age group in percentage of individuals. We assumed this to equate to cases per 100 individuals and converted this series to cases per 100,000 individuals by multiplying each datapoint by 1,000. The CDC data were not provided according to the same age groups as our model; therefore, we used a fourth-order polynomial fitting technique to adjust the CDC prevalence data to align with our age groups.

### Alzheimer’s Disease

We sourced the mortality, prevalence, and incidence data for Alzheimer’s disease from the Alzheimer’s Association’s “Alzheimer’s Disease Facts and Figures” report (2024). Data were available for all three disease characteristics for the 65–74, 75–84 and 85+ years age groups. The source also provided mortality data for the 45–54 and 55–64 years age groups, and prevalence data for the 30–64 years age group.

1. Alzheimer’s disease mortality: Our source provided mortality data in deaths per 100,000 individuals and no further transformations were required.
2. Alzheimer’s disease incidence: Our source recorded incidence data for Alzheimer’s disease in percentage of individuals, which we interpreted as cases per 100 individuals. To convert these figures into cases per 100,000 individuals, we multiplied each incidence data point by 1,000.
3. Alzheimer’s disease prevalence: For age groups 65–74, 75–84, and 85+ years, prevalence data were recorded in percentage of individuals, which we interpreted as cases per 100 individuals. To convert these data into cases per 100,000 persons, we multiplied each datapoint by 1,000. The source also reported the prevalence for age group 30–64 years in cases per 100,000 individuals, so no further transformations were required.

## Disease-Climate Links

Hurricane affected proportion of the U.S. population: To account for the proportion of the United Stated that is affected by hurricanes, we developed a scaling factor to adjust each of the hurricane-related inputs below by the proportion of the total U.S. population (328.24 million) (Johnson, 2019) that resides in the most hurricane-prone regions (60.2 million) (Cohen, 2019) according to 2019 U.S. Census estimates, as below:

(60.2 m i l l i o n)/(328.24 m i l l i o n) = 0.185534974

We assumed that the populations of both the hurricane-prone regions and the United States as a whole will grow at similar rates and that this proportion will remain constant over the study period.

### Climate and All-Cause Mortality

1. Extreme heat: We found a source in the literature (Anderson and Bell, 2011) that reported a 3.74 percent (95% CI 2.29–5.22) increase in all-cause mortality due to a heat wave. To obtain the percentage increase in all-cause mortality for each extra day of extreme heat, we divided by the average length of a heatwave in the 2020s (4.3 days) (Johnson, 2019; EPA, undated-a).
2. Hurricanes: We found a source in the literature (Huang et al., 2023) that reported the relative risk for deaths due to exposure to a cyclone or hurricane as 1.09 (95% CI 1.04–1.13), which can be interpreted as an estimated increase in the risk of mortality of 9 percent, with the true mortality risk most likely falling between 4 and 13 percent. To account for the affected proportion of the United States, we scaled down by multiplying these figures by 0.185534974.
3. PM2.5: We found a source in the literature (Wang et al., 2020) that reported the relative risk for total deaths due to exposure to an additional 10 μg/m^3^ of PM2.5 as 1.05 (95% CI 1.044–1.056). These can be interpreted as an estimated increase in mortality risk of 5 percent, with the true risk of mortality most likely falling between 4.4 and 5.6 percent.
4. Ozone: We found a source in the literature (Kim, Kim, and Kim, 2020) that reported the hazard ratio for total deaths due to exposure to an additional 10 ppb of ozone as 1.01 (95% CI 1.01–1.01). These can be interpreted as an estimated increase in mortality of 1 percent, with the true value most likely also falling within the 1 percent range. Due to the need to provide a varied confidence interval for sampling during the simulations, we adjusted the upper and lower bounds of the percentage interpretation to 0.99 percent to 1.01 percent, respectively.

### Climate and Cardiovascular Disease Mortality

1. Extreme heat: We found a source in the literature (Khatana, Werner, and Groeneveld, 2022) that reported the percent increase in CVD mortality due to exposure to an additional day of extreme heat as 0.12 percent (95% CI 0.04–0.21).
2. Hurricanes: We found a source in the literature (Huang et al., 2023) that reported the relative risk for CVD-related deaths due to exposure to a cyclone or hurricane as 1.14 (95% CI 0.99–1.3), which can be interpreted as an estimated increase in the risk of mortality of 14 percent per cyclone or hurricane. To account for the affected proportion of the United States, we scaled down by multiplying these figures by 0.185534974.
3. PM 2.5: We found a source in the literature (Manisalidis et al., 2020) that reported the relative risk for cardiovascular deaths due to exposure to an additional 10 μg/m^3^ of PM2.5 as 1.088 (95% CI 1.078–1.098), which can be interpreted as an estimated increase in the risk of mortality of 8.8 percent, with the true increased risk of mortality most likely falling between 7.8 percent to 9.8 percent.
4. Ozone: We found a source in the literature (Wang et al., 2020) that reported the hazard ratio for CVD-related deaths due to exposure to an additional 10 ppb of ozone as 1.03 (95% CI 1.01–1.06), which can be interpreted as an estimated increase in mortality of 3 percent, with the most likely true increase in mortality falling between 1 percent to 6 percent.

### Climate and Cardiovascular Disease Incidence

1. Extreme heat: We found a source in the literature (Singh et al., 2024) that reported the relative risk of CVD morbidity due to a heat wave as 1.008 (95% CI 0.998–1.017), which can be interpreted as an estimated increase of 0.8 percent, with the true change in morbidity most likely falling between–0.2 percent and 1.7 percent. To obtain the percentage increase in all-cause mortality for each extra day of extreme heat, we divided these figures by the average length of a heatwave in the 2020s (4.3 days).
2. Hurricanes: We were unable to find data that directly related hurricanes to changes in the incidence of CVD. However, we did find a source in the literature (Swerdel et al., 2014) that reported the attributable rate ratio of myocardial infarctions specifically due to hurricanes or cyclones as 1.22 (95% CI 1.16–1.28), which we assume to be similar to the percentage increase in CVD overall. Therefore, these figures can be interpreted as an increase in CVD incidence of 22 percent, with the true increase in CVD incidence most likely falling between 16 percent and 28 percent. To account for the affected proportion of the United States, we scaled down by multiplying these figures by 0.185534974.
3. PM2.5: We found a source in the literature (Xi et al., 2022) that reported the hazard ratio for CVD incidence due to exposure to an additional 10 μg/m^3^ of PM2.5 as 1.03 (95% CI1.02–1.04), which can be interpreted as an estimated increase in CVD incidence of 3 percent, with the true change in CVD incidence most likely falling between 2 percent and 4 percent.
4. Ozone: We found a source in the literature (Wu et al., 2022) that reported the percentage increase in CVD incidence due to exposure to an additional 10 ppb of ozone as 1.42 percent (95% CI 0.14–2.73).

### Climate and End-Stage Renal Disease Mortality

1. Extreme heat: We found a source in the literature (Blum et al., in press) that reported the hazard ratio of ESRD mortality due to an extreme heat event as 1.18 (95% CI 1.15–1.20). This can be interpreted as an increase in ESRD mortality of 18 percent, with the true increase in mortality most likely falling between 15 percent and 20 percent. To obtain the percentage increase in ESRD mortality for each extra day of extreme heat, we divided these figures by the average length of a heatwave in the 2020s (4.3 days) according to the EPA (undated-a).
2. Hurricanes: We found a source in the literature (Blum et al., 2022) that reported the hazard ratio for ESRD-related deaths due to exposure to a cyclone or hurricane as 1.13 (95% CI 1.06–1.22), which can be interpreted as an estimated increase in mortality of 13 percent, with the true increase in mortality most likely falling between 6 percent and 22 percent. To account for the affected proportion of the United States, we scaled down by multiplying these figures by 0.185534974.
3. PM2.5: We found a source in the literature (Xi et al., 2020) that reported the relative risk for ESRD-related deaths due to exposure to an additional 10 μg/m^3^ of PM2.5 as 1.01 (95% CI 1.001–1.019), which can be interpreted as an estimated increase in mortality of 1 percent, with the true risk of death most likely falling between 0.1 percent and 1.9 percent.
4. Ozone: We found a source in the literature (Kim et al., 2024) that reported the hazard ratio for ESRD-related deaths due to exposure to an additional 10 ppb of ozone as 1.012 (95% CI 1.008–1.017), which can be interpreted as an estimated increase in mortality of 1.2 percent, with the true value most likely falling between 0.8 percent and 1.7 percent.

### Climate and End-Stage Renal Disease Incidence

1. Extreme heat: We were unable to find data that directly related change in the incidence of ESRD with heat waves. However, we did find a source in the literature (Bobb et al., 2014) that reported the relative risk of ESRD-related hospitalizations due to a heat wave as 1.14 (95% CI 1.06–1.23), which we interpreted as an increase in ESRD-related morbidity of 14 percent. To obtain the percentage increase in ESRD incidence for each extra day of extreme heat, we divided these figures by the average length of a heat wave in the 2020s (4.3 days) according to the EPA (undated-a).
2. Hurricanes: We found a source in the literature (Howard et al., 2012) that reported the percentage of excess renal-related hospitalizations due to a hurricane as 3 percent (95% CI 2.86–3.7). To account for the affected proportion of the United States, we scaled down by multiplying these figures by 0.185534974.
3. PM2.5: We found a source in the literature (Wathanavasin et al., 2024) that reported the odds ratio for ESRD incidence due to exposure to an additional 10 μg/m^3^ of PM2.5 as 1.16 (95% CI 1.00–1.36), which can be interpreted as an estimated increase in incidence of 16 percent, with the true change most likely falling between of 0 percent and 36 percent.
4. Ozone: We found a source in the literature (Kim et al., 2024) that reported the hazard ratio for ESRD incidence due to exposure to an additional 10 ppb of ozone as 1.049 (95% CI 1.044–1.054), which can be interpreted as an estimated increase in incidence of 4.9 percent, with the true change most likely falling between 4.4 percent and 5.4 percent.

### Climate and Asthma Mortality

1. Extreme heat: We found a source in the literature (Cheng et al., 2019) that reported the relative risk of asthma mortality due to a heat wave as 1.08 (95% CI 1.01–1.160) which can be interpreted as an estimated increase in asthma mortality of 8 percent, with the true change most likely falling between 1 percent and 16 percent. To obtain the percentage increase in asthma-related mortality for each extra day of extreme heat, we divided these figures by the average length of a heatwave in the 2020s (4.3 days) according to the EPA (undated-a).
2. Hurricanes: We found a source in the literature (Huang et al., 2023) that reported the percentage change in respiratory deaths due to exposure to a cyclone or hurricane as 1.3 percent (95% CI 0.2–2.4). To account for the affected proportion of the United States, we scaled down by multiplying these figures by 0.185534974.
3. PM2.5: We found a source in the literature (Song et al., 2022) that reported the percentage change in asthma-related deaths due to exposure to an additional 10 μg/m^3^ of PM2.5 as 2.39 percent (95% CI 0.05–4.78).
4. Ozone: We found a source in the literature (Kim, Kim, and Kim, 2020) that reported the hazard ratio for asthma-related deaths due to exposure to an additional 10 ppb of ozone as 1.04 (95% CI 1.01–0.07), which can be interpreted as an estimated increase in mortality of 4 percent, with the true change most likely falling between 1 percent and 7 percent.

### Climate and Asthma Incidence

1. Extreme heat: We were unable to find data that directly measured the relationship between extreme heat and change in asthma incidence, therefore we used a source in the literature (Soneja et al., 2016) that reported the odds ratio of same-day hospitalizations for asthma due to an extreme heat day as 1.03 (95% CI 1.00–1.07), which can be interpreted as an estimated increase in asthma morbidity of 3 percent, with the true change most likely falling between 0 percent and 7 percent.
2. Hurricanes: We were unable to find data that directly measured the relationship between extreme heat and change in asthma incidence, therefore we used a source in the literature (Makrufardi et al., 2023) that reported the relative risk for asthma events due to exposure to a cyclone or hurricane as 1.5 (95% CI 0.93–2.43), which can be interpreted as an estimated increase in asthma morbidity of 50 percent, with the true change in morbidity most likely falling between −7 percent and 143 percent. To account for the affected proportion of the United States, we scaled down by multiplying these figures by 0.185534974.
3. PM2.5: We found a source in the literature (Khalili et al., 2018) that reported the odds ratio for asthma diagnosis due to exposure to an additional 5.9 μg/m^3^ of PM2.5 as 1.08 (95% CI 1.0–1.15), which can be interpreted as an estimated increase in asthma incidence of 8 percent, with the true change in incidence most likely falling between 0 percent and 15 percent. To obtain the change in incidence due to exposure to an additional 10 μg/m^3^ of PM2.5, we divided these figures by 5.9 and multiplied the results by 10.
4. Ozone: We were unable to find data that directly measured the relationship between exposure to ozone and change in asthma incidence, therefore we used a source in the literature (Li et al., 2019) that reported the relative risk for asthma exacerbations due to exposure to an additional 10 μg/m^3^ of ozone as 1.014 (95% CI 1.005–1.024). These can be interpreted as an estimated increase in asthma incidence of 1.4 percent, with the true change in asthma incidence most likely falling between 0.5 percent and 2.4 percent. To standardize the units to 10 ppb of ozone, we multiplied these figures by 1.996 as 1 ppb of ozone is equivalent to 1.996 μg/m.^3^

### Climate and Alzheimer’s Disease Mortality

1. Extreme heat: We found a source in the literature (Yin et al., 2023) that reported the relative risk of death due to an extreme heat day among patients with Alzheimer’s disease as 1.3 (95% CI 1.23–1.38), which can be interpreted as an estimated increase in Alzheimer’s mortality of 30 percent, with the true change in mortality risk most likely falling between 23 percent and 38 percent.
2. Hurricanes: We found data in the literature (Bell et al., 2023) that reported the relative risk of death due to hurricane exposure among patients with Alzheimer’s disease or other related dementias as 1.08 (95% CI 1.07–1.09), which can be interpreted as an estimated increase in mortality among patients with Alzheimer’s disease of 8 percent, with the true change in risk of death most likely falling between 7 percent and 9 percent. To account for the affected proportion of the United States, we scaled down by multiplying these figures by 0.185534974.
3. PM2.5: We were unable to find specific data for the effect of PM2.5 on the risk of death among patients with Alzheimer’s disease, but we found a study in the literature (Wang et al., 2022) that assessed the impact of PM 2.5 exposure on mortality among Medicare beneficiaries; since this population also accounts for the vast majority of Alzheimer’s patients, we assumed that the percentage changes in mortality due to the effect of PM2.5 would be similar. The study reported the hazard ratio for total mortality due to exposure to an additional 2.63 μg/m^3^ of PM2.5 as 1.025 (95% CI 1.023–1.027), which estimates a mortality increase of 2.5 percent, with the true mortality change most likely falling between 2.3 percent and 2.7 percent. These units were standardized with our other PM2.5 variables and converted into effect per 10 μg/m^3^ of PM2.5 by dividing by 2.63 and multiplying the results by 10.
4. Ozone: We were unable to find specific data for the effect of ground-level ozone on Alzheimer’s patient mortality, but we found one study in the literature that assessed the impact of ozone exposure on dementia mortality (Zhao et al., 2021). We assumed that these percentage changes would be similar. This source reported the hazard ratio for dementia related deaths due to exposure to an additional 10.1 ppb of ozone as 1.08 (95% CI 1.06–1.10), which can be interpreted as an estimated increase in mortality of 8 percent, with the true change in mortality most likely falling between 6 percent and 10 percent. We divided the percentages by 10.1 and multiplied the results by 10 to convert them into effect per 10 ppb of ozone.

### Alzheimer’s Disease Incidence

1. Extreme heat: We were unable to find data that directly investigated the impact of extreme heat exposure on Alzheimer’s disease incidence, however we found a source in the literature (Xu et al., 2019) that reported the percentage increase in Alzheimer’s-related hospitalizations due to a heat wave as 51 percent (95% CI 2.0–126.0). To obtain the percentage increase in Alzheimer’s related hospitalizations for each extra day of extreme heat, we divided these figures by the average length of a heat wave in the 2020s (4.3 days) according to the EPA (undated-a).
2. Hurricanes: We were unable to find data that directly investigated the impact of hurricane exposure on Alzheimer’s incidence, however, we found a source (Bell et al., 2021) in the literature that reported the incidence rate ratio for all-cause hospital admissions among Medicare beneficiaries during a hurricane. We assume that these rates will be similar. The study reported the admissions rate ratio as 1.23 (95% CI 1.22–1.24), which can be interpreted as an estimated increase in of 23 percent, with the true change in admissions most likely falling between 22 percent and 24 percent. To account for the affected proportion of the United States, we scaled down by multiplying these figures by 0.185534974.
3. PM2.5: We found a source in the literature (Yang et al., 2022) that reported the hazard ratio for Alzheimer’s disease incidence due to exposure to an additional 10 μg/m^3^ of PM2.5 as 1.05 (95% CI 1.01–1.10), which can be interpreted as an estimated increase in the incidence of Alzheimer’s disease of 5 percent, with the true change in incidence most likely falling between 1 percent and 10 percent.
4. Ozone: We found a source in the literature (Jung, Lin, and Hwang, 2015) that reported the hazard ratio for Alzheimer’s disease incidence due to exposure to an additional 9.63 ppb of ozone as 1.06 (95% CI 1.00–1.12), which can be interpreted as an estimated increase in incidence of 6 percent, with the true change in incidence most likely falling between 0 percent and 12 percent. We divided the percentages by 9.63 and multiplied the results by 10 to standardize the units to 10 ppb of ozone.

## Human Mortality Database U.S. Life Table

We used data from the Total (both sexes), 1x1, Life Tables dataset as provided by the Human Mortality Database. No changes were made to the source data (Human Mortality Database, undated).

## U.S. Births

To project births in the U.S. between 2024 and 2040, we used data from the “Projected Births by Sex, Race, and Hispanic Origin for the United States: 2023 to 2100” dataset as projected by the U.S. Census “2023 National Population Projections.” No changes were made to the source data (U.S. Census Bureau, undated).

## U.S. Deaths

To project deaths in the U.S. between 2024 and 2040, we used data from the “Projected Deaths by Single Year of Age, Sex, Race, and Hispanic Origin for the United States: 2023 to 2100” dataset as projected by the U.S. Census “2023 National Population Projections.” No changes were made to the source data (U.S. Census Bureau, undated).

## U.S. Net Migration

To project net migration to the U.S. between 2024 and 2040, we used data from the “Projected Net International Migration by Single Year of Age, Sex, Race, and Hispanic Origin for the United States: 2023 to 2100” dataset as projected by the U.S. Census “2023 National Population Projections.” No changes were made to the source data (U.S. Census Bureau, undated).

## U.S. Total Population

To project the total population of the U.S. between 2024 and 2040, we used data from the “Projected Population by Single Year of Age, Sex, Race, and Hispanic Origin for the United States: 2022 to 2100” dataset as projected by the U.S. Census “2023 National Population Projections.” No changes were made to the source data (U.S. Census Bureau, undated).