# Appendix B Technical Model Details

This appendix provides additional technical details on the structure of the model to supplement the methods as written in Chapter 3. Specific details on data sources, inputs, and transformations are available in Appendix C.

## Model Design

Given the age-structured nature of our model, we maintain separate compartments, also known as state variables, for each clinical state within each age group. Specifically, we denote T_i_ as the population diagnosed with a given disease, for example, CVD, and receiving treatment in age group i. H_i_ represents the healthy population in age group i, and D_i_ denotes the deceased population in age group i. These compartments, T_i_, H_i_, and D_i_, represent the different conditions individuals can be in over time. The state variables are updated as time (denoted by t) progresses in the model simulation.

The dynamics of our model are governed by a set of coupled ODEs. These equations determine how individuals move between different compartments over time. They also account for demographic changes, such as births and migration. In our model, the rate at which individuals enter the healthy population via birth or migration for age group i is denoted by μ_i_. The rate at which individuals age from one group to the next (for example, from age group i to age group i + 1) is denoted by α_i_.

For simplicity, we assume that no individuals are born with a given disease and that immigrants do not enter the system already diagnosed with a disease. Our model explicitly accounts for aging within both the healthy and diagnosed populations as part of the demographic dynamics.

New cases of a disease (incidence) are represented by the movement of individuals from the Healthy Population to the Diagnosed and Treated Population. This transition is governed by age-specific hazard rates, denoted by λ_i_, which represents the annual risk of a healthy individual developing and being diagnosed with a disease. Deaths within each age group i are accounted for by two rates: the all-other-cause mortality rate (μ_Oi_) and the disease-specific mortality rate (μ_Ti_), both of which can change over time (t). For our baseline scenario, these rates are based on existing U.S. Census Bureau projections (U.S. Census Bureau, undated). For our climate change scenarios, these rates are adjusted to reflect the impact of extreme weather events related to climate change.

Although our model uses annual rates for input parameters, we convert these to daily rates (i.e., divide by 365) since our model operates on a daily time scale. This conversion allows us to capture the dynamics of disease progression and treatment more accurately on a finer, day-to-day basis.

Based on the described state variables and transition rates, our model is formulated by the following set of coupled ODEs (1) through (3):

(d H_i_)/(d t) = π_i_ − (λ_i_ + μ_O i_) H_i_ + (α_i − 1_ H_i − 1_ − α_i_ H_i_) (1)

(d T_i_)/(d t) = λ_i_ H_i_ − (μ_O i_ + μ_T i_) T_i_ + (α_i − 1_ T_i − 1_ − α_i_ T_i_) (2)

(d D_i_)/(d t) = μ_O i_ (H_i_ + T_i_) + μ_T i_ T_i_ . (3)

These interconnected ODEs are numerically integrated in R version 4.2.2 using the deSolve package (Soetaert, Petzoldt, and Setzer, 2010).

## Informing the Baseline Model

### Population Dynamics

Our chosen approach enabled us to describe and reproduce baseline demographic projections over time. We aggregated raw Census data related to deaths, net migration, and population into specified age groups, based on a combination of disease-specific factors and the format in which incidence and mortality data were reported (see Appendix C). Using this aggregated data, we defined inflow rates (including births and net migration) and outflow rates (including predicted deaths by age group) to create Census-based projections. For projected births, we used annual totals aggregated across all demographics (e.g., race), without further breakdown by factors such as gender or age group. For deaths and net migration, the data were aggregated by specified age groups, ensuring that projections accounted for demographic categories such as race and gender within those groups. Finally, total population projections were compiled to support model development, providing key insights into population dynamics across age groups and demographic factors as they evolve over time.

Following a self-consistency verification, we used our forecast for total deaths by age group from 2024 to 2040 to extract mortality scaling factors for each age group, s_i_(t). Here, t represents the time in years since our initial year of 2024. Initially, s_i_(t = 0) is set to one for 2024, meaning no adjustment is needed for the base year. As we project into future years, s_i_(t) adjusts to reflect changing mortality trends. Mathematically, the scaling factor S_i_ ( t ) = (D_i_ ( t ))/(N_i_ ( t )) ⋅ (N_i_ ( 0 ))/(D_i_ ( 0 )) , where N_i_(t) and D_i_(t) are Census-provided populations and deaths in age group i in year t. By definition, s_i_(0) = 1 for all age groups. These scaling factors are integrated into our ODE model to adapt mortality rates over time, ensuring that our model accurately reflects projected demographic dynamics and is consistent with actual population trends.

We also incorporated U.S. life tables from the Human Mortality Database to estimate aging rates and for verification purposes (Human Mortality Database, undated-a). While the Census provides annual predictions of deaths by age, offering detailed insights into demographic trends over time, the U.S. life tables offer comprehensive mortality data adjusted for underreporting, age misreporting, and other biases, ensuring accurate mortality rates across different age groups. These tables also aggregate mortality data for both genders, providing gender-neutral mortality rates essential for demographic modeling. We estimated the aging rate for how individuals transition from one age group to the next, α_i_ by computing l_x_, which represents the number of individuals out of 100,000 who survive to each age x, based on the life table mortality rate m_x_ for each year. By summing these l_x_ values for each age group, we determine the total number of survivors within that group, ensuring that we account for the cumulative survival of the cohort up to that age. The proportion for the last age in each group indicates the annual fraction of individuals aging out of that age group transitioning to the next.

## Informing the Disease-Specific Rates

After establishing the baseline demographic rates in our model, the next step involves incorporating disease-specific inputs, including initial conditions (i.e., the populations of healthy individuals and those diagnosed with the disease) and transition rates for each age group. After estimating disease prevalence, we distributed the total population N_i_(0) of each age group into those diagnosed with the disease, denoted as T_i_(0), and the healthy population, denoted as H_i_(0). Therefore, the prevalence for age group i is simply given by T_i_(0)/N_i_(0).

Equally important to establishing baseline inputs is determining the initial disease-specific mortality rates, μ_Ti_(0), and hazard rates, λ_i_(0), for each age group. These rates are pivotal for forecasting how disease prevalence will evolve over time. We derived the disease-specific mortality rates from various sources and adjusted to match our age groupings (see Appendix C).

Having obtained the initial values for T_i_(0) and H_i_(0) from the prevalence data and the disease-specific mortality rates, μ_Ti_(0), for each age group, we proceeded to estimate the initial age group-specific all-other-cause mortality rates, μ_Oi_(0). This estimation was derived from the all-cause mortality given by the Census data, denoted as (D_i_ ( 0 ))/(N_i_ ( 0 )) , which must equal the sum of all-other-cause mortality applied to the healthy population H_i_(0) and the combined all-other-cause and disease-specific mortality applied to the diseased population T_i_(0). Mathematically, this relationship is expressed by equation (5):

μ_O i_ ( 0 ) H_i_ ( 0 ) + [μ_O i_ ( 0 ) + μ_T i_ ( 0 )] T_i_ ( 0 ) = D_i_ ( 0 ) . (5)

This equation essentially balances the contributions of mortality from other causes (i.e., not the disease of interest) from both the healthy population (H_0_) and the diagnosed population (T_0_) against the total deaths (D_0_) observed in the initial year. Solving this equation (equation (6)) provides an estimate of the initial all-other-cause mortality μ_Oi_(0), which is crucial for accurately modeling the overall mortality dynamics within each age group in subsequent years.

μ_O i_ ( 0 ) = (D_i_ ( 0 ) − μ_T i_ ( 0 ) T_i_ ( 0 ))/(N_i_ ( 0 )) . (6)

Incidence data, or historic data on prevalence trends by age group, can be used to estimate the initial hazard rates λ_i_(0). When further accounting for demographic aging dynamics, this relationship is mathematically expressed by equation (7):

[μ_O i_ ( 0 ) + μ_T i_ ( 0 ) + α_i_] T_i_ ( 0 ) = λ_i_ ( 0 ) H_i_ ( 0 ) + α_i − 1_ T_i − 1_ ( 0 ) (7)

Rearranging this equation, we have equation (8),

λ_i_ ( 0 ) = {[μ_O i_ ( 0 ) + μ_T i_ ( 0 ) + α_i_] T_i_ ( 0 ) − α_i − 1_ T_i − 1_ ( 0 )} / H_i_ ( 0 ) (8)

Having obtained the baseline initial disease-specific mortality rates, μ_Ti_(0), all-other-cause mortality rates, μ_Oi_(0), and hazard rates, λ_i_(0), for each age group, we then project these values for future years. To ensure consistency with Census population projections, we assume that the relationship (or ratio) of disease prevalence between the age groups remains stationary over time. Under this assumption, the projected values for each future year t are given by: μ_Oi_(t) = s_i_(t)μ_Oi_(0), μ_Ti_(t) = s_i_(t)μ_Ti_(0) and λ_i_(t) = s_i_(t)λ_i_(0). Here, s_i_(t) is the scaling factor that adjusts for changes in overall mortality trends observed in the Census data for age group i. By applying these scaling factors, we ensure that our model remains aligned with demographic dynamics and accurately reflects future population changes.

## Verification of Population Dynamics, Initial Conditions, and Baseline Rates Input

We conducted a self-consistency verification that involved comparing the population growth dynamics derived from integrating births, deaths, migration, and aging data against historic Census-provided population growth data. We found that errors across all age groups remained within ±2 percent, and over time the positive and negative errors balanced each other out, confirming that our demographic projections closely match Census data by the end of the study period and validating this aspect of our model.

We also conducted a self-consistency verification of the initial conditions and baseline rates. We used the initial conditions along with all our initial baseline rate inputs and their expected changes over time and entered these into our model with numerically integrated model ODEs.

This aimed to ensure that the ODE-generated population dynamics were consistent with the Census projections. We found excellent agreement between the model’s projections and the Census data with errors ± 0.3 percent.

## Fine-Tuning Incidence Rates for 2024 Baseline Prevalence Projections

In our modeling of the four diseases, we fine-tuned the baseline scenario (i.e., no climate change effects) incidence rates to ensure that our 2040 prevalence estimates aligned closely with other models available in the literature that forecast future disease prevalence without incorporating the impact of climate change. To achieve target 2040 prevalence for the baseline scenario, we modified incidences rather than mortalities, as disease-specific mortality data are generally more precise than incidence data. Here are the specific adjustments made for each disease, as shown in Table 3.1.

- For CVD, we adjusted the estimated incidence rate to reflect a projected increase in prevalence from 9.8 percent in 2015 to 14.0 percent in 2040. This adjustment corresponds to a 43-percent increase in prevalence from the 2024 baseline scenario to 2040 (i.e., 14.0 percent/9.8 percent) (Ortendahl et al., 2019).
- For asthma, we adjusted the estimated incidence rate to reflect an assumed 5 percent increase in prevalence by 2040 relative to 2024 in the baseline scenario. This estimate was informed by existing projections that forecast a rise in asthma prevalence among people under age 18 from 8 percent to 14 percent by 2090 (Neumann et al., 2019). Using the upper bound estimate (14 percent), we assumed a linear trend and estimated a 5 percent increase by 2040.
- For ESRD, we adjusted the incidence rate to reflect an assumed 34-percent increase in prevalence from the 2024 baseline scenario to 2040 based on global trends and adjusted for the specific demographic and health care context of the United States (CDC, 2023; GBD Chronic Kidney Disease Collaboration, 2020).
- For Alzheimer’s disease, we adjusted the incidence rate to reflect an assumed 45-percent increase in prevalence by 2040 relative to 2024 in the baseline scenario. This projection was based on global trends and adjusted for the specific demographics and health care context of the United States (Institute for Health Metrics and Evaluation, undated; Akushevich et al., 2023).