# Appendix A Environmental Scan Search Strategy

Table A.1 Search Strategy of PubMed Database

Set No. | Search | No. of results
1 | “United States”[tiab] OR “U.S.”[tiab] OR “US”[tiab] OR “USA”[tiab] OR “U.S.A.”[tiab] OR Alabama[tiab] OR Alaska[tiab] OR Arizona[tiab] OR Arkansas[tiab] OR California[tiab] OR Colorado[tiab] OR Connecticut[tiab] OR Delaware[tiab] OR “District of Columbia”[tiab] OR Florida[tiab] OR Georgia[tiab] OR Hawaii[tiab] OR “Hawai i”[tiab] OR Idaho[tiab] OR Illinois[tiab] OR Indiana[tiab] OR Iowa[tiab] OR Kansas[tiab] OR Kentucky[tiab] OR Louisiana[tiab] OR Maine[tiab] OR Maryland[tiab] OR Massachusetts[tiab] OR Michigan[tiab] OR Minnesota[tiab] OR Mississippi[tiab] OR Missouri[tiab] OR Montana[tiab] OR Nebraska[tiab] OR Nevada[tiab] OR “New Hampshire”[tiab] OR “New Jersey”[tiab] OR “New Mexico”[tiab] OR “New York”[tiab] OR “North Carolina”[tiab] OR “North Dakota”[tiab] OR Ohio[tiab] OR Oklahoma[tiab] OR Oregon[tiab] OR Pennsylvania[tiab] OR “Rhode Island”[tiab] OR “South Carolina”[tiab] OR “South Dakota”[tiab] OR Tennessee[tiab] OR Texas[tiab] OR Utah[tiab] OR Vermont[tiab] OR Virginia[tiab] OR Washington[tiab] OR “West Virginia”[tiab] OR Wisconsin[tiab] OR Wyoming[tiab] OR Huntsville[tiab] OR Montgomery[tiab] OR Anchorage[tiab] OR Fairbanks[tiab] OR Tafuna[tiab] OR Phoenix[tiab] OR Tucson[tiab] OR “Little Rock”[tiab] OR Fayetteville[tiab] OR “Los Angeles”[tiab] OR “San Diego”[tiab] OR Denver[tiab] OR “Colorado Springs”[tiab] OR Bridgeport[tiab] OR Stamford[tiab] OR Wilmington[tiab] OR Jacksonville[tiab] OR Miami[tiab] OR Atlanta[tiab] OR Columbus[tiab] OR Honolulu[tiab] OR Boise[tiab] OR Chicago[tiab] OR Aurora[tiab] OR Indianapolis[tiab] OR “Fort Wayne”[tiab] OR “Des Moines”[tiab] OR “Cedar Rapids”[tiab] OR Wichita[tiab] OR “Overland Park”[tiab] OR Louisville[tiab] OR Lexington[tiab] OR “New Orleans”[tiab] OR “Baton Rouge”[tiab] OR Baltimore[tiab] OR Boston[tiab] OR Worcester[tiab] OR Detroit[tiab] OR “Grand Rapids”[tiab] OR Minneapolis[tiab] OR “Kansas City”[tiab] OR Billings[tiab] OR Missoula[tiab] OR Omaha[tiab] OR Lincoln[tiab] OR “Las Vegas”[tiab] OR Nashua[tiab] OR Newark[tiab] OR “Jersey City”[tiab] OR Albuquerque[tiab] OR “Las Cruces”[tiab] OR Charlotte[tiab] OR Raleigh[tiab] OR Fargo[tiab] OR Bismarck[tiab] OR Dandan[tiab] OR Cleveland[tiab] OR Tulsa[tiab] OR Portland[tiab] OR Salem[tiab] OR Philadelphia[tiab] OR Pittsburgh[tiab] OR “San Juan”[tiab] OR Bayamon[tiab] OR Providence[tiab] OR Warwick[tiab] OR Charleston[tiab] OR “Sioux Falls”[tiab] OR “Rapid City”[tiab] OR Nashville[tiab] OR Memphis[tiab] OR Houston[tiab] OR “San Antonio”[tiab] OR “Salt Lake City”[tiab] OR “West Valley City”[tiab] OR Burlington[tiab] OR Chesapeake[tiab] OR Seattle[tiab] OR Spokane[tiab] OR Huntington[tiab] OR Milwaukee[tiab] OR Madison[tiab] OR Cheyenne[tiab] OR Casper[tiab] OR “United States”[Mesh] OR “Puerto Rico”[Mesh] OR Guam[Mesh] OR “Los Angeles”[Mesh] OR “San Francisco”[Mesh] OR “Chicago”[Mesh] OR “New York City”[Mesh] OR “Baltimore”[Mesh] OR “Philadelphia”[Mesh] OR “Boston”[Mesh] OR “New Orleans”[Mesh] | 2,155,158
2 | (asthma*[tiab] OR “Asthma”[Mesh]) | 208,271
3 | (albuterol*[tiab] OR “albuterol sulfate”[tiab] OR “albuterol ipratropium”[tiab:~1] OR Levalbuterol[tiab] OR Proventil[tiab] OR Salbutamol[tiab] OR Sultanol[tiab] OR “Salmeterol Xinafoate”[tiab] OR Ventolin[tiab] OR “Fluticasone Salmeterol”[tiab] OR “Formoterol Fumarate”[tiab] OR “Albuterol”[Mesh]) | 14,969
4 | #1 AND #2 AND #3 AND (2013/12/31:2024/12/31[pdat]) AND (english[Filter]) | 118
5 | “heart failure*”[tiab] OR “heart attack*”[tiab] OR “myocardial failure*”[tiab] OR “myocardial infarction*”[tiab] OR “myocardial ischemia”[tiab] OR “Heart Failure”[Mesh] OR “Myocardial Infarction”[Mesh] OR “Myocardial Ischemia”[Mesh] OR “Cardiomyopathies”[MAJR] OR stroke[tiab] OR strokes[tiab] OR “cerebrovascular disease*”[tiab] OR “cerebrovascular disorder*”[tiab] OR “cerebrovascular accident*”[tiab] OR “Stroke”[Mesh] OR “Cerebrovascular Disorders”[Mesh] | 1,381,791
6 | Metoprolol[tiab] OR Toprol*[tiab] OR Lopressor*[tiab] OR “Metoprolol”[Mesh] | 9,127
7 | #1 AND #5 AND #6 AND (2013/12/31:2024/12/31[pdat]) AND (english[Filter]) | 47
8 | Coccidioidomycosis[tiab] OR Coccidiomycosis[tiab] OR “Coccidioides infection”[tiab:~1] OR “Coccidioides infections”[tiab:~1] OR Coccidioidal[tiab] OR “San Joaquin Valley Fever”[tiab] OR “Coccidioidomycosis”[Mesh] | 4,014
9 | Amphotericin[tiab] OR Amphocil[tiab] OR “Amphotericin B”[Mesh] | 27,692
10 | #1 AND #8 AND #9 AND (2013/12/31:2024/12/31[pdat]) AND (english[Filter]) | 23
11 | (“chronic kidney disease*”[tiab] OR “chronic kidney insufficienc*”[tiab] OR “chronic renal insufficienc*”[tiab] OR “chronic renal failure*”[tiab] OR “chronic kidney failure*”[tiab] OR “chronic kidney disorder*”[tiab] OR “chronic kidney injur*”[tiab] OR “chronic renal injur*”[tiab] OR “end stage kidney disease*”[tiab] OR “end stage renal disease*”[tiab] OR dialysis[tiab] OR hemodialys*[tiab] OR “hemodiafiltration”[tiab] OR “renal dialysis”[tiab] OR “Renal Insufficiency, Chronic”[Mesh] OR “Kidney Failure, Chronic”[Mesh] OR “Renal Dialysis”[Mesh]) | 328,277
12 | (heparin*[tiab] OR LMWH*[tiab] OR Dalteparin[tiab] OR Enoxaparin[tiab] OR Nadroparin[tiab] OR Tinzaparin[tiab] OR Heparin[Mesh]) | 117,002
13 | #1 AND #11 AND #12 AND (2013/12/31:2024/12/31[pdat]) AND (english[Filter]) | 47
14 | (Alzheimer*[tiab] OR “Alzheimer Disease”[Mesh]) | 215,257
15 | (Donepezil[tiab] OR “Donepezil”[Mesh] OR Aricept[tiab] OR Galantamin*[tiab] OR Nivalin[tiab] OR Reminyl[tiab] OR “Galantamine”[Mesh] OR Rivastigmine[tiab] OR Exelon[tiab] OR Rivastigmine[Mesh]) | 8,265
16 | #1 AND #14 AND #15 AND (2013/12/31:2024/12/31[pdat]) AND (english[Filter]) | 79

Table A.2 Search Strategy of CINAHL Database

Set No. | Search | No. of Results
1 | (TI “United States” OR AB “United States”) OR (TI U.S. OR AB U.S.) OR (TI USA OR AB USA) OR (TI U.S.A. OR AB U.S.A.) OR (TI Alabama OR AB Alabama) OR (TI Alaska OR AB Alaska) OR (TI Arizona OR AB Arizona) OR (TI Arkansas OR AB Arkansas) OR (TI California OR AB California) OR (TI Colorado OR AB Colorado) OR (TI Connecticut OR AB Connecticut) OR (TI Delaware OR AB Delaware) OR (TI “District of Columbia” OR AB “District of Columbia”) OR (TI Florida OR AB Florida) OR (TI Georgia OR AB Georgia) OR (TI Hawaii OR AB Hawaii) OR (TI “Hawai i” OR AB “Hawai i”) OR (TI Idaho OR AB Idaho) OR (TI Illinois OR AB Illinois) OR (TI Indiana OR AB Indiana) OR (TI Iowa OR AB Iowa) OR (TI Kansas OR AB Kansas) OR (TI Kentucky OR AB Kentucky) OR (TI Louisiana OR AB Louisiana) OR (TI Maine OR AB Maine) OR (TI Maryland OR AB Maryland) OR (TI Massachusetts OR AB Massachusetts) OR (TI Michigan OR AB Michigan) OR (TI Minnesota OR AB Minnesota) OR (TI Mississippi OR AB Mississippi) OR (TI Missouri OR AB Missouri) OR (TI Montana OR AB Montana) OR (TI Nebraska OR AB Nebraska) OR (TI Nevada OR AB Nevada) OR (TI “New Hampshire” OR AB “New Hampshire”) OR (TI “New Jersey” OR AB “New Jersey”) OR (TI “New Mexico” OR AB “New Mexico”) OR (TI “New York” OR AB “New York”) OR (TI “North Carolina” OR AB “North Carolina”) OR (TI “North Dakota” OR AB “North Dakota”) OR (TI Ohio OR AB Ohio) OR (TI Oklahoma OR AB Oklahoma) OR (TI Oregon OR AB Oregon) OR (TI Pennsylvania OR AB Pennsylvania) OR (TI “Rhode Island” OR AB “Rhode Island”) OR (TI “South Carolina” OR AB “South Carolina”) OR (TI “South Dakota” OR AB “South Dakota”) OR (TI Tennessee OR AB Tennessee) OR (TI Texas OR AB Texas) OR (TI Utah OR AB Utah) OR (TI Vermont OR AB Vermont) OR (TI Virginia OR AB Virginia) OR (TI Washington OR AB Washington) OR (TI “West Virginia” OR AB “West Virginia”) OR (TI Wisconsin OR AB Wisconsin) OR (TI Wyoming OR AB Wyoming) OR (TI Huntsville OR AB Huntsville) OR (TI Montgomery OR AB Montgomery) OR (TI Anchorage OR AB Anchorage) OR (TI Fairbanks OR AB Fairbanks) OR (TI Tafuna OR AB Tafuna) OR (TI Phoenix OR AB Phoenix) OR (TI Tucson OR AB Tucson) OR (TI “Little Rock” OR AB “Little Rock”) OR (TI Fayetteville OR AB Fayetteville) OR (TI “Los Angeles” OR AB “Los Angeles”) OR (TI “San Diego” OR AB “San Diego”) OR (TI Denver OR AB Denver) OR (TI “Colorado Springs” OR AB “Colorado Springs”) OR (TI Bridgeport OR AB Bridgeport) OR (TI Stamford OR AB Stamford) OR (TI Wilmington OR AB Wilmington) OR (TI Jacksonville OR AB Jacksonville) OR (TI Miami OR AB Miami) OR (TI Atlanta OR AB Atlanta) OR (TI Columbus OR AB Columbus) OR (TI Honolulu OR AB Honolulu) OR (TI Boise OR AB Boise) OR (TI Chicago OR AB Chicago) OR (TI Aurora OR AB Aurora) OR (TI Indianapolis OR AB Indianapolis) OR (TI “Fort Wayne” OR AB “Fort Wayne”) OR (TI “Des Moines” OR AB “Des Moines”) OR (TI “Cedar Rapids” OR AB “Cedar Rapids”) OR (TI Wichita OR AB Wichita) OR (TI “Overland Park” OR AB “Overland Park”) OR (TI Louisville OR AB Louisville) OR (TI Lexington OR AB Lexington) OR (TI “New Orleans” OR AB “New Orleans”) OR (TI “Baton Rouge” OR AB “Baton Rouge”) OR (TI Baltimore OR AB Baltimore) OR (TI Boston OR AB Boston) OR (TI Worcester OR AB Worcester) OR (TI Detroit OR AB Detroit) OR (TI “Grand Rapids” OR AB “Grand Rapids”) OR (TI Minneapolis OR AB Minneapolis) OR (TI “Kansas City” OR AB “Kansas City”) OR (TI Billings OR AB Billings) OR (TI Missoula OR AB Missoula) OR (TI Omaha OR AB Omaha) OR (TI Lincoln OR AB Lincoln) OR (TI “Las Vegas” OR AB “Las Vegas”) OR (TI Nashua OR AB Nashua) OR (TI Newark OR AB Newark) OR (TI “Jersey City” OR AB “Jersey City”) OR (TI Albuquerque OR AB Albuquerque) OR (TI “Las Cruces” OR AB “Las Cruces”) OR (TI Charlotte OR AB Charlotte) OR (TI Raleigh OR AB Raleigh) OR (TI Fargo OR AB Fargo) OR (TI Bismarck OR AB Bismarck) OR (TI Dandan OR AB Dandan) OR (TI Cleveland OR AB Cleveland) OR (TI Tulsa OR AB Tulsa) OR (TI Portland OR AB Portland) OR (TI Salem OR AB Salem) OR (TI Philadelphia OR AB Philadelphia) OR (TI Pittsburgh OR AB Pittsburgh) OR (TI “San Juan” OR AB “San Juan”) OR (TI Bayamon OR AB Bayamon) OR (TI Providence OR AB Providence) OR (TI Warwick OR AB Warwick) OR (TI Charleston OR AB Charleston) OR (TI “Sioux Falls” OR AB “Sioux Falls”) OR (TI “Rapid City” OR AB “Rapid City”) OR (TI Nashville OR AB Nashville) OR (TI Memphis OR AB Memphis) OR (TI Houston OR AB Houston) OR (TI “San Antonio” OR AB “San Antonio”) OR (TI “Salt Lake City” OR AB “Salt Lake City”) OR (TI “West Valley City” OR AB “West Valley City”) OR (TI Burlington OR AB Burlington) OR (TI Chesapeake OR AB Chesapeake) OR (TI Seattle OR AB Seattle) OR (TI Spokane OR AB Spokane) OR (TI Milwaukee OR AB Milwaukee) OR (TI Madison OR AB Madison) OR (TI Cheyenne OR AB Cheyenne) OR (TI Casper OR AB Casper) OR (MH “United States+”) OR (MH “Puerto Rico”) OR (MH “Guam”) | 972,684
2 | (TI asthma* OR AB asthma*) OR (MH “Asthma+”) | 50,490
3 | (TI albuterol* OR AB albuterol*) OR (TI “albuterol sulfate” OR AB “albuterol sulfate”) OR (TI “albuterol ipratropium” OR AB “albuterol ipratropium”) OR (TI Levalbuterol OR AB Levalbuterol) OR (TI Proventil OR AB Proventil) OR (TI Salbutamol OR AB Salbutamol) OR (TI Sultanol OR AB Sultanol) OR (TI “Salmeterol Xinafoate” OR AB “Salmeterol Xinafoate”) OR (TI Ventolin OR AB Ventolin) OR (TI “Fluticasone Salmeterol” OR AB “Fluticasone Salmeterol”) OR (TI “Formoterol Fumarate” OR AB “Formoterol Fumarate”) OR (MH “Albuterol”) | 3,086
4 | S1 AND S2 AND S3 Limits: 2013 – 2024; English; Academic Journals | 58
5 | (TI “heart failure*” OR AB “heart failure*”) OR (TI “heart attack*” OR AB “heart attack*”) OR (TI “myocardial failure*” OR AB “myocardial failure*”) OR (TI “myocardial infarction*” OR AB “myocardial infarction*”) OR (TI “myocardial ischemia” OR AB “myocardial ischemia”) OR (MH “Heart Failure+”) OR (MH “Myocardial Infarction+”) OR (MH “Myocardial Ischemia+”) OR (MM Cardiomyopathies+) OR (TI stroke OR AB stroke) OR (TI strokes OR AB strokes) OR (TI “cerebrovascular disease*” OR AB “cerebrovascular disease*”) OR (TI “cerebrovascular disorder*” OR AB “cerebrovascular disorder*”) OR (TI “cerebrovascular accident*” OR AB “cerebrovascular accident*”) OR (MH “Stroke+”)OR (MH “Cerebrovascular Disorders”) | 325,693
6 | (TI Metoprolol OR AB Metoprolol) OR (TI Toprol* OR AB Toprol*) OR (TI Lopressor* OR AB Lopressor*) OR (MH “Metoprolol”) | 1,457
7 | S1 AND S5 AND S6 Limits: 2013 – 2024; English; Academic Journals | 25
8 | (TI Coccidioidomycosis OR AB Coccidioidomycosis) OR (TI Coccidiomycosis OR AB Coccidiomycosis) OR (TI “Coccidioides infection*” OR AB “Coccidioides infection*”) OR (TI Coccidioidal OR AB Coccidioidal) OR (TI “San Joaquin Valley Fever” OR AB “San Joaquin Valley Fever”) OR (MH “Coccidioidomycosis”) | 601
9 | (TI Amphotericin OR AB Amphotericin) OR (TI Amphocil OR AB Amphocil) OR (MH “Amphotericin B”) | 2,759
10 | S1 AND S8 AND S9 Limits: 2013 – 2024; English; Academic Journals | 4
11 | (TI “chronic kidney disease*” OR AB “chronic kidney disease*”) OR (TI “chronic kidney insufficienc*” OR AB “chronic kidney insufficienc*”) OR (TI “chronic renal insufficienc*” OR AB “chronic renal insufficienc*”) OR (TI “chronic renal failure*” OR AB “chronic renal failure*”) OR (TI “chronic kidney failure*” OR AB “chronic kidney failure*”) OR (TI “chronic kidney disorder*” OR AB “chronic kidney disorder*”) OR (TI “chronic kidney injur*” OR AB “chronic kidney injur*”) OR (TI “chronic renal injur*” OR AB “chronic renal injur*”) OR (TI “end stage kidney disease*” OR AB “end stage kidney disease*”) OR (TI “end stage renal disease*” OR AB “end stage renal disease*”) OR (TI dialysis OR AB dialysis) OR (TI hemodialys* OR AB hemodialys*) OR (TI hemodiafiltration OR AB hemodiafiltration) OR (TI “renal dialysis” OR AB “renal dialysis”) OR (MH “Renal Insufficiency, Chronic+”) OR (MH “Kidney Failure, Chronic”) OR (MH “Dialysis”) OR (MH “Dialysis Patients”) | 70,277
12 | (TI heparin* OR AB heparin*) OR (TI LMWH* OR AB LMWH*) OR (TI Dalteparin OR AB Dalteparin) OR (TI Enoxaparin OR AB Enoxaparin) OR (TI Nadroparin OR AB Nadroparin) OR (TI Tinzaparin OR AB Tinzaparin) OR (MH “Heparin+”) OR (MH “Heparin, Low-Molecular-Weight”) OR (MH “Dalteparin Sodium”) OR (MH “Tinzaparin Sodium”) | 16,005
13 | S1 AND S11 AND S12Limits: 2013 – 2024; English; Academic Journals | 14
14 | (TI Alzheimer* OR AB Alzheimer*) OR (MH “Alzheimer’s Disease”) | 53,037
15 | ((TI Donepezil OR AB Donepezil) OR (TI Aricept OR AB Aricept) OR (TI Galantamin* OR AB Galantamin*) OR (TI Nivalin OR AB Nivalin) OR (TI Reminyl OR AB Reminyl) OR (TI Rivastigmine OR AB Rivastigmine) OR (TI Exelon OR AB Exelon) OR (MH “Donepezil”) OR (MH “Galanthamine”) OR (MH “Rivastigmine”) | 2,388
16 | S1 AND S14 AND S15 Limits: 2013 – 2024; English; Academic Journals | 26

Table A.3 Search Strategy of Web of Science Database

Set No. | Search | No. of results
1 | TI=(“United States” OR “U.S.” OR “USA” OR “US” OR “U.S.A.” OR Alabama OR Alaska OR Arizona OR Arkansas OR California OR Colorado OR Connecticut OR Delaware OR “District of Columbia” OR Florida OR Georgia OR Hawaii OR “Hawai i” OR Idaho OR Illinois OR Indiana OR Iowa OR Kansas OR Kentucky OR Louisiana OR Maine OR Maryland OR Massachusetts OR Michigan OR Minnesota OR Mississippi OR Missouri OR Montana OR Nebraska OR Nevada OR “New Hampshire” OR “New Jersey” OR “New Mexico” OR “New York” OR “North Carolina” OR “North Dakota” OR Ohio OR Oklahoma OR Oregon OR Pennsylvania OR “Rhode Island” OR “South Carolina” OR “South Dakota” OR Tennessee OR Texas OR Utah OR Vermont OR Virginia OR Washington OR “West Virginia” OR Wisconsin OR Wyoming OR Huntsville OR Montgomery OR Anchorage OR Fairbanks OR Phoenix OR Tucson OR “Little Rock” OR Fayetteville OR “Los Angeles” OR “San Diego” OR Denver OR “Colorado Springs” OR Bridgeport OR Stamford OR Wilmington OR Jacksonville OR Miami OR Atlanta OR Honolulu OR Boise OR Chicago OR Indianapolis OR “Fort Wayne” OR “Des Moines” OR “Cedar Rapids” OR Wichita OR “Overland Park” OR Louisville OR “New Orleans” OR “Baton Rouge” OR Baltimore OR Boston OR Detroit OR “Grand Rapids” OR Minneapolis OR “Kansas City” OR Billings OR Missoula OR Omaha OR “Las Vegas” OR Nashua OR “Jersey City” OR Albuquerque OR “Las Cruces” OR Raleigh OR Fargo OR Cleveland OR Tulsa OR Portland OR Salem OR Philadelphia OR Pittsburgh OR “San Juan” OR Charleston OR “Sioux Falls” OR “Rapid City” OR Nashville OR Memphis OR Houston OR “San Antonio” OR “Salt Lake City” OR “West Valley City” OR Burlington OR Seattle OR Spokane OR Milwaukee) OR AB=(“United States” OR “U.S.” OR “USA” OR “U.S.A.” OR Alabama OR Alaska OR Arizona OR Arkansas OR California OR Colorado OR Connecticut OR Delaware OR “District of Columbia” OR Florida OR Georgia OR Hawaii OR “Hawai i” OR Idaho OR Illinois OR Indiana OR Iowa OR Kansas OR Kentucky OR Louisiana OR Maine OR Maryland OR Massachusetts OR Michigan OR Minnesota OR Mississippi OR Missouri OR Montana OR Nebraska OR Nevada OR “New Hampshire” OR “New Jersey” OR “New Mexico” OR “New York” OR “North Carolina” OR “North Dakota” OR Ohio OR Oklahoma OR Oregon OR Pennsylvania OR “Rhode Island” OR “South Carolina” OR “South Dakota” OR Tennessee OR Texas OR Utah OR Vermont OR Virginia OR Washington OR “West Virginia” OR Wisconsin OR Wyoming OR Huntsville OR Montgomery OR Anchorage OR Fairbanks OR Phoenix OR Tucson OR “Little Rock” OR Fayetteville OR “Los Angeles” OR “San Diego” OR Denver OR “Colorado Springs” OR Bridgeport OR Stamford OR Wilmington OR Jacksonville OR Miami OR Atlanta OR Honolulu OR Boise OR Chicago OR Indianapolis OR “Fort Wayne” OR “Des Moines” OR “Cedar Rapids” OR Wichita OR “Overland Park” OR Louisville OR “New Orleans” OR “Baton Rouge” OR Baltimore OR Boston OR Detroit OR “Grand Rapids” OR Minneapolis OR “Kansas City” OR Billings OR Missoula OR Omaha OR “Las Vegas” OR Nashua OR “Jersey City” OR Albuquerque OR “Las Cruces” OR Raleigh OR Fargo OR Cleveland OR Tulsa OR Portland OR Salem OR Philadelphia OR Pittsburgh OR “San Juan” OR Charleston OR “Sioux Falls” OR “Rapid City” OR Nashville OR Memphis OR Houston OR “San Antonio” OR “Salt Lake City” OR “West Valley City” OR Burlington OR Seattle OR Spokane OR Milwaukee) | 1,878,497
2 | TI=(asthma*) OR AB=(asthma*) | 190,596
3 | TI=(albuterol* OR “albuterol sulfate” OR “albuterol ipratropium” OR Levalbuterol OR Proventil OR Salbutamol OR Sultanol OR “Salmeterol Xinafoate” OR Ventolin OR “Fluticasone Salmeterol” OR “Formoterol Fumarate”) OR AB=(albuterol* OR “albuterol sulfate” OR “albuterol ipratropium” OR Levalbuterol OR Proventil OR Salbutamol OR Sultanol OR “Salmeterol Xinafoate” OR Ventolin OR “Fluticasone Salmeterol” OR “Formoterol Fumarate”) | 11,641
4 | (#1 AND #2 AND #3) AND (PY==(“2024” OR “2023” OR “2022” OR “2021” OR “2020” OR “2019” OR “2018” OR “2017” OR “2016” OR “2015” OR “2014” OR “2013”) AND DT==(“ARTICLE” OR “REVIEW” OR “EARLY ACCESS”) AND LA==(“ENGLISH”)) | 57
5 | TI=(“heart failure*” OR “heart attack*” OR “myocardial failure*” OR “myocardial infarction*” OR “myocardial ischemia” OR cardiomyopath* OR stroke OR strokes OR “cerebrovascular disease*” OR “cerebrovascular disorder*” OR “cerebrovascular accident*”) OR AB=(“heart failure*” OR “heart attack*” OR “myocardial failure*” OR “myocardial infarction*” OR “myocardial ischemia” OR cardiomyopath* OR stroke OR strokes OR “cerebrovascular disease*” OR “cerebrovascular disorder*” OR “cerebrovascular accident*”) | 876,631
6 | TI=(Metoprolol OR Toprol* OR Lopressor*) OR AB=(Metoprolol OR Toprol* OR Lopressor*) | 8,204
7 | (#1 AND #5 AND #6) AND (PY==(“2024” OR “2023” OR “2022” OR “2021” OR “2020” OR “2019” OR “2018” OR “2017” OR “2016” OR “2015” OR “2014” OR “2013”) AND DT==(“ARTICLE” OR “REVIEW” OR “EARLY ACCESS”) AND LA==(“ENGLISH”)) | 19
8 | TI=(Coccidioidomycosis OR Coccidiomycosis OR “Coccidioides infection*” OR Coccidioidal OR “San Joaquin Valley Fever”) OR AB=(Coccidioidomycosis OR Coccidiomycosis OR “Coccidioides infection*” OR Coccidioidal OR “San Joaquin Valley Fever”) | 2,355
9 | TI=(Amphotericin* OR Amphocil) OR AB=(Amphotericin* OR Amphocil) | 20,068
10 | (#1 AND #8 AND #9) AND (PY==(“2024” OR “2023” OR “2022” OR “2021” OR “2020” OR “2019” OR “2018” OR “2017” OR “2016” OR “2015” OR “2014” OR “2013”) AND DT==(“ARTICLE” OR “REVIEW” OR “EARLY ACCESS”) AND LA==(“ENGLISH”)) | 16
11 | TI=(“chronic kidney disease*” OR “chronic kidney insufficienc*” OR “chronic renal insufficienc*” OR “chronic renal failure*” OR “chronic kidney failure*” OR “chronic kidney disorder*” OR “chronic kidney injur*” OR “chronic renal injur*” OR “end stage kidney disease*” OR “end stage renal disease*” OR dialysis OR hemodialys* OR “hemodiafiltration” OR “renal dialysis”) OR AB=(“chronic kidney disease*” OR “chronic kidney insufficienc*” OR “chronic renal insufficienc*” OR “chronic renal failure*” OR “chronic kidney failure*” OR “chronic kidney disorder*” OR “chronic kidney injur*” OR “chronic renal injur*” OR “end stage kidney disease*” OR “end stage renal disease*” OR dialysis OR hemodialys* OR “hemodiafiltration” OR “renal dialysis”) | 271,362
12 | TI=(heparin* OR LMWH* OR Dalteparin OR Enoxaparin OR Nadroparin OR Tinzaparin) OR AB=(heparin* OR LMWH* OR Dalteparin OR Enoxaparin OR Nadroparin OR Tinzaparin) | 91,914
13 | (#1 AND #11 AND #12) AND (PY==(“2024” OR “2023” OR “2022” OR “2021” OR “2020” OR “2019” OR “2018” OR “2017” OR “2016” OR “2015” OR “2014” OR “2013”) AND DT==(“ARTICLE” OR “REVIEW” OR “EARLY ACCESS”) AND LA==(“ENGLISH”)) | 35
14 | TI=(Alzheimer*) OR AB=(Alzheimer*) | 211,663
15 | TI=(Donepezil OR Aricept OR Galantamin* OR Nivalin OR Reminyl OR Rivastigmine OR Exelon) OR AB=(Donepezil OR Aricept OR Galantamin* OR Nivalin OR Reminyl OR Rivastigmine OR Exelon) | 8,701
16 | (#1 AND #14 AND #15) AND (PY==(“2024” OR “2023” OR “2022” OR “2021” OR “2020” OR “2019” OR “2018” OR “2017” OR “2016” OR “2015” OR “2014” OR “2013”) AND DT==(“ARTICLE” OR “REVIEW” OR “EARLY ACCESS”) AND LA==(“ENGLISH”)) | 62

NOTE: Web of Science Core Collection: Science Citation Index Expanded (SCI-EXPANDED), Social Sciences Citation Index (SSCI), Emerging Sources Citation Index (ESCI).

Table A.4 Search Strategy of Grey Literature

Search Parameter | Details
Any of these words | “drug utilization” \| “drug usage” \| “prescription statistic*” \| “prescribed drug statistic*” \| “total purchase*” \| “drug shortage*” \| “drug prescriptions statistical data”
This exact word or phrase | ((Albuterol* OR “albuterol sulfate” OR “albuterol ipratropium” OR Levalbuterol OR Proventil OR Salbutamol OR Sultanol OR “Salmeterol Xinafoate” OR Ventolin OR “Fluticasone Salmeterol” OR “Formoterol Fumarate”) AND asthma) Metoprolol OR Toprol* OR Lopressor* OR “Metoprolol” (Amphotericin OR Amphocil OR “Amphotericin B”) AND (“San Joaquin Valley Fever”[tiab] OR Coccidioidomycosis) ((Heparin* OR Enoxaparin OR Nadroparin OR Tinzaparin) AND (“kidney disease” OR hemodialysis)) ((Donepezil OR Aricept OR Galantamine OR Nivalin OR Reminyl OR Rivastigmine OR Exelon) AND Alzheimer)
Limited to these site domains (.gov, .org) | AAP, AHRQ, AMA, CDC, FDA, HHSEPA, IOM/NAM, IQVIA, National Academies, NSF, WHO
Year limits | 2014–2024