# References

Burns, C. “Three-Quarters of Pharmacists Say Lack of Staff is Hindering Their Job Performance.” The Pharmaceutical Journal, October 27, 2021. https://pharmaceutical-journal.com/article/news/three-quarters-of-pharmacists-say-lack-of-staff-is-hindering-their-job-performance. Accessed January 11, 2024.
Centers for Disease Control and Prevention. “Partnering for Vaccine Equity: Equity in Vaccination.” https://web.archive.org/web/20240518223224/https:/www.cdc.gov/vaccines/health-equity/index.html. Page last updated September 2023. Accessed May 18, 2024.
Damschroder, L.J., C.M. Reardon, M.A. Opera Widerquest, and J. Lowery. “The Updated Consolidated Framework for Implementation Research Based on User Feedback.” Implementation Science, vol. 17, no. 75. 2022.
Guide to Community Preventive Services. Vaccination Programs: Health Care System-Based Interventions Implemented in Combination. https://www.thecommunityguide.org/findings/vaccination-programs-health-care-system-based-interventions-implemented-combination.html. Page last updated September 2, 2015. Accessed January 11, 2024.
Health Resources and Services Administration. “Community-Based Outreach to Build COVID-19 Vaccine Confidence.” https://www.hrsa.gov/coronavirus/community-based-outreach. Page last updated November, 2022. Accessed May 13, 2024.
Jewell, N.P. Statistics for Epidemiology, 1st Edition. Chapman and Hall/CRC. 2003.
Kaufman, L., and P.J. Rousseeuw. Finding Groups in Data: An Introduction to Cluster Analysis. John Wiley & Sons, Inc. 1990.
Leider, J.P., B.C. Castrucci, M. Robins, R.H. Bork, M.R. Fraser, E. Savoia, R. Piltch-Loeb, and H.K. Koh. “The Exodus of State and Local Public Health Employees: Separations Started Before and Continued Throughout COVID-19.” Health Affairs, vol. 42, no. 3, March 2023. https://www.healthaffairs.org/doi/10.1377/hlthaff.2022.01251. Accessed January 11, 2024.
Rockefeller Foundation. “Sustaining and Explaining Vaccine Equity: Lessons from the Equity-First Vaccination Initiative.” 2024. https://www.rockefellerfoundation.org/covid-19-response/creating-vaccine-equity/. Accessed May 13, 2024.
Rousseeuw, P.J. “Silhouettes: A Graphical Aid to the Interpretation and Validation of Cluster Analysis.” Journal of Computational and Applied Mathematics, vol. 20, 1987, pp. 53–65.