# Executive Summary

This report presents findings from the National Survey on Best Practices for COVID-19 Vaccination and Testing, part of the Best Practices for COVID-19 Testing and Vaccination Study sponsored by the Office of the Assistant Secretary for Planning and Evaluation (ASPE) and the Office of the Assistant Secretary for Health (OASH). Mathematica, ASPE, and OASH designed the survey to gather information from local organizations about their efforts to improve COVID-19 testing and vaccination in populations that are medically or socially at disproportionate risk for COVID-19 or related adverse outcomes.

Mathematica administered the survey from September to November 2023 to five types of local organizations: local health departments (LHDs); Federally Qualified Health Centers (FQHCs); community-based organizations (CBOs); community pharmacies; and Indian Health Service, tribal, and Urban Indian Organization (I/T/U) health facilities. These organizations were located in 22 states, which we selected on the basis of geographic diversity, vulnerability to COVID-19, and high rates of series vaccination (see Methods section). We then constructed a sample of organizations in each state by stratifying the LHDs, FQHCs, CBOs, and pharmacies between urban areas and all other areas and selecting randomly within each stratum. For the I/T/U facilities, we implicitly stratified the sample by service unit to ensure that the sample was broadly representative of I/T/U facilities across the state, then randomly selecting facilities.

We invited 507 representatives in 22 states to complete the survey and 475 of them were found to be eligible for the study. We received 164 completed surveys, for an overall response rate of 35% among those eligible. Response rates are similar for most organization types (32% – 41%) but notably lower for Indian Health Services facilities (0%) and tribal facilities (26%). Because we did not receive any responses from Indian Health Services facilities, this report refers to tribal and Urban Indian Organization (T/U) facilities only.

Findings from this analysis of survey data are primarily descriptive and serve to broaden our understanding of the testing and vaccination strategies that local organizations used most frequently, their populations of focus, the challenges they experienced in helping those populations, and other attributes of their efforts that address our research questions and provide context for data from site visits.

Findings do not generalize to all organizations of a given type included in this study or to other organizations within survey states. All descriptions of findings refer to organizations that responded to the survey rather than all organizations of a given type. We present unweighted results because findings are exploratory and descriptive, rather than representative of the population of organizations.

Key findings

- The vast majority (72%) of respondents worked on both COVID-19 testing and vaccination. Similarities between their testing and vaccination strategies, partnerships, and populations of focus suggest that respondents applied strategies from testing to vaccination, or they bundled services.
- Respondents used roughly seven testing or vaccination strategies on average; some reported using large numbers of strategies, up to 17 out of 18 possible response options. Respondents from FQHCs and LHDs reported the largest number of different strategies, and pharmacies reported the fewest. Because respondents summarized their organizations’ experiences over more than three years, it is not clear from the survey data which strategies they used simultaneously versus sequentially, as the pandemic unfolded.
- The most commonly reported strategies were similar across organization types. Partnering with community organizations and trusted leaders was a common strategy for both testing and vaccination.
- Partnerships with government, medical, and community organizations were more common than partnerships with businesses or faith-based organizations, but there were key exceptions by organization type. LHDs tended to use partnerships the most, and with the greatest range of partners, while pharmacies partnered the least.
- LHDs and FQHCs reported the broadest range of populations of focus for services, whereas pharmacies and T/U facilities reported the fewest. Respondents from all organization types focused on serving older adults, while incarcerated persons were the least commonly reported population of focus. Focusing on younger adults was also common.
- Respondents focused on specific populations in line with their organizational missions. For example, CBOs and FQHCs focused on people facing economic insecurity, including people without health insurance and people with low income.
- Staffing was the most common challenge overall, by a substantial margin, consistent with widely reported shortages in the health care and public health workforces during and after the pandemic.
- Respondents more commonly reported challenges internal to their organizations and facilitators that were external to their organizations, reflecting that many organizations might not have been well set up internally to deliver testing or vaccination services, at least right away, and therefore needed supports from outside.
- Federal funding was the most commonly reported source of funding overall. Within organization types, the most commonly reported source aligned with typical funding sources, such as local or state funding for LHDs and private insurance for pharmacies. Common testing and vaccination strategies were largely the same regardless of funding source.
- The most commonly reported sources of information for planning were community guides, community-level data (about COVID-19 disease, testing, or vaccination rates), and information or best practices from federal programs. LHDs, FQHCs, and CBOs used the most sources of information to develop their COVID-19 testing or vaccination strategies, whereas pharmacies used the fewest.
- Respondents typically assessed their success by looking at outputs rather than health outcomes. Commonly reported outputs included numbers of vaccine doses and tests delivered, adherence to CDC guidelines, and participants’ satisfaction.