# VI Methods

Here, we describe sampling methods, survey administration, and analysis methods. More details about sampling methods and survey administration are in the final survey plan submitted to ASPE on May 10, 2023. We received IRB approval for the survey on May 17, 2023, and clearance by the Office of Management and Budget (OMB) under the Paperwork Reduction Act on September 12^th^, 2023 (OMB control number 0990-0421).

## A Sampling methods

### 1 Sample frame

To develop the sample frame, we first selected 22 states. We prioritized (1) geographic diversity based on census regions and divisions; (2) states most vulnerable to the impacts of COVID-19 as reflected by high scores for the overall COVID-19 Community Vulnerability Index score; and (3) high rates of series vaccination as of August 31, 2021, using CDC COVID-19 Vaccination Trends data. These state characteristics allowed us to select a geographically diverse sample. We gave some preference to states with I/T/U facilities.

We then developed a sample of LHDs, FQHCs, CBOs, I/T/U facilities, and community pharmacies to invite to participate in the study. We worked with ASPE, the Office of the Assistant Secretary for Health (OASH), and the project’s expert panel to help identify the appropriate organizations using the following sources:

- LHDs. We programmatically extracted the LHD information from the National Association of County and City Health Officials LHD directory website (https://www.naccho.org/membership/lhd-directory) to build a database of all LHDs in the selected states. This directory provides an exhaustive list of all LHDs. Rhode Island has no LHDs, and therefore, we invited the Rhode Island Department of Health to participate.
- FQHCs. We accessed a database of FQHCs and FQHC look-alikes for each selected state from the Health Resources and Services Administration website (https://data.hrsa.gov/data/reports/datagrid?gridName=FQHCs). This database provides an exhaustive list of FQHCs and FQHC look-alikes.
- CBOs. We joined lists of CBOs from CDC and the CDC Foundation’s Partnering for Vaccine Equity grantees,^10^ the Rockefeller Foundation’s Equity First Vaccination Initiative,^11^ and the Health Resources and Services Administration’s Community-Based Outreach to Build COVID-19 Vaccine Confidence grantees^12^ to form our sample frame of CBOs that provided or promoted vaccinations. These sources provide a diverse list of CBOs but is not exhaustive of all CBOs providing or promoting testing and vaccination.
- I/T/U facilities. We used a list that included Indian Health Service facilities, tribal facilities, and Urban Indian Organizations that was from the Indian Health Service web site. This site provides an exhaustive list of Indian Health Service facilities, tribal facilities, and Urban Indian Organizations.
- Pharmacies. We used the member organizations of the National Community Pharmacists Association as the source of our sample frame. The association’s member list is exhaustive of all members (over 19,400 independent pharmacies), however not all independent pharmacies are members.

### 2 Sampling organizations

The total invited sample of 507 organizations was divided among the five organization types and 22 selected states. Before drawing the sample, we stratified the LHDs, FQHCs, CBOs, and pharmacies between urban areas and all other areas. Within each stratum defined by organization type and urban/all other areas, we randomly selected organizations. For the I/T/U facilities, we implicitly stratified the sample by service unit to ensure that the sample was broadly representative of I/T/U facilities across the state. I/T/U facilities were randomly selected.

Exhibit IV.1 shows the distribution of sampled organizations by state and Exhibit IV.2 shows the sample frame in each state, or the total number of organizations of each type in each state from which we drew the sample.

Exhibit VI.1 Distribution of sampled organizations by state

State | LHDs | FQHCs | CBOs | I/T/U facilities | Pharmacies | Total
AK | 2 | 4 | 3 | 17 | 7 | 33
AL | 4 | 4 | 4 | 2 | 4 | 18
AZ | 5 | 5 | 5 | 8 | 5 | 28
CA | 5 | 5 | 6 | 9 | 5 | 30
FL | 5 | 5 | 5 | 5 | 5 | 25
IL | 5 | 5 | 5 | 1 | 5 | 21
IN | 5 | 5 | 6 | 0 | 5 | 21
KS | 4 | 4 | 4 | 4 | 4 | 20
MA | 10 | 5 | 5 | 3 | 5 | 28
MI | 5 | 5 | 5 | 6 | 5 | 26
MO | 5 | 5 | 5 | 1 | 5 | 21
MS | 4 | 4 | 4 | 4 | 4 | 20
NC | 5 | 5 | 5 | 6 | 5 | 26
NJ | 6 | 5 | 5 | 0 | 5 | 21
NM | 4 | 4 | 4 | 6 | 4 | 22
NV | 4 | 4 | 4 | 5 | 4 | 21
NY | 5 | 5 | 5 | 5 | 5 | 25
OK | 4 | 4 | 5 | 7 | 4 | 24
OR | 4 | 4 | 4 | 5 | 4 | 21
RI | 1 | 4 | 5 | 2 | 4 | 16
TX | 5 | 5 | 5 | 4 | 5 | 24
WV | 4 | 4 | 4 | 0 | 4 | 16
Total | 101 | 100 | 103 | 100 | 103 | 507

Exhibit VI.2 Total organizations in the sample frame

State | LHDs | FQHCs | CBOs | I/T/U facilities | Pharmacies | Total
AK | 2 | 28 | 3 | 288 | 7 | 328
AL | 72 | 19 | 17 | 2 | 314 | 424
AZ | 15 | 22 | 13 | 67 | 92 | 209
CA | 62 | 206 | 90 | 106 | 501 | 965
FL | 66 | 54 | 33 | 5 | 366 | 524
IL | 95 | 50 | 53 | 1 | 224 | 423
IN | 94 | 39 | 8 | 0 | 117 | 258
KS | 100 | 21 | 5 | 9 | 148 | 283
MA | 353 | 37 | 16 | 3 | 94 | 503
MI | 45 | 40 | 33 | 23 | 353 | 494
MO | 114 | 30 | 10 | 1 | 245 | 400
MS | 84 | 21 | 15 | 8 | 160 | 288
NC | 86 | 43 | 28 | 16 | 280 | 453
NJ | 109 | 24 | 38 | 0 | 228 | 399
NM | 58 | 19 | 4 | 38 | 26 | 145
NV | 17 | 8 | 5 | 23 | 9 | 62
NY | 58 | 69 | 45 | 11 | 414 | 597
OK | 71 | 21 | 5 | 70 | 206 | 373
OR | 32 | 34 | 10 | 22 | 36 | 134
RI | 1 | 8 | 5 | 2 | 5 | 21
TX | 109 | 73 | 47 | 4 | 586 | 819
WV | 49 | 30 | 19 | 0 | 118 | 216
Total | 1692 | 896 | 502 | 699 | 4529 | 8318

Note: The number of each organization type varies across states because each state’s health and social services system is different. The numbers in the sample frame therefore reflect the universe of organizations in each state. For example, there are many I/T/U facilities in Alaska and few CBOs compared to other states.

We selected a backup sample for all five organization types for each state in the strata (urban and all other areas) in case we needed to replace a sampled organization. Ultimately, we decided not to release the backup sample because the response by organization type was relatively equal and the level of response was on target (see Exhibit I.1 on page 1 of the Introduction section).

## B Survey administration

### 1 Survey mode, length, and fielding procedures

Mathematica designed and administered the National Survey on Best Practices for COVID-19 Vaccination and Testing survey as a web survey and a paper survey, estimated to take 15 minutes to complete based on pretesting feedback. We used Confirmit, a state-of-the-art survey platform, to manage survey administration. After programming the survey, the survey team comprehensively tested the web instrument, checking the content, skip-logic, and overall flow to ensure that it operated as intended. We entered data from the paper instruments into the Confirmit application.

We administered the survey over a 10-week fielding period from September 19, 2023, to November 27, 2023. We identified a point of contact at each sampled organization and located mailing and email addresses through the data sources used to select the sample and other online sources.

In September, we mailed an invitation letter to potential respondents with an identified address (n = 495) to request their participation in the survey. The invitation letter included a link to the web survey and a unique survey login ID and password so respondents could easily access the web survey. We also included a QR code that respondents could scan instead of entering their username and password.

Along with the invitation letter, we sent an invitation email to potential respondents with an identified email address (n = 507) inviting them to complete the survey. The email referenced the invitation letter, so respondents knew to look for it in the mail. Instead of a QR code, the email invitation included a link to the survey unique to each respondent. We sent seven reminder emails during weeks two, three, five, six, nine, and two in week 10. During week four, we mailed a paper questionnaire, reminder letter, and informational one-pager, along with a prepaid return envelope, to nonrespondents. During week six, we mailed a reminder letter accompanied by an informational one-pager to nonrespondents. Finally, telephone interviewers conducted reminder calls to encourage nonrespondents to complete the web or paper survey from week seven through week 10. Interviewers made three attempts to reach each nonrespondent by phone. We provided a $50 check to nongovernmental respondents that completed the survey. Exhibit VI.3 presents the full communication plan.

Exhibit VI.3 Survey communication plan

Fielding week | Dates | Survey communications
Week 1 | September 19 to September 25 | Invitation mailing; Email invitation
Week 2 | September 26 to October 2 | Email reminder #1
Week 3 | October 3 to October 9 | Email reminder #2
Week 4 | October 10 to October 16 | Hard copy mailing
Week 5 | October 17 to October 23 | Email reminder #3
Week 6 | October 24 to October 30 | Email reminder #4; Reminder mailing
Week 7 | October 31 to November 6 | Reminder calls
Week 8 | November 7 to 13 | Reminder calls
Week 9 | November 14 to 20 | Reminder calls; Email reminder #5
Week 10 | November 21 to 27 | Reminder calls; Email reminders #6 and #7

### 2 Survey response rates

We obtained a 35% response rate, or 164 completed surveys. Exhibit VI.4 shows response rates by organization type. All organization types completed at least one survey, with the exception of Indian Health Service facilities. Therefore, all completed I/T/U surveys are from representatives of T/U health facilities.

Exhibit VI.4 Response rates by organization type

Survey status | LHDs (n = 101) | FQHCs (n = 100) | CBOs (n = 103) | I/T/U facilities (n = 100) | | | Pharmacies (n = 103) | Total (n = 507)
Survey status | LHDs (n = 101) | FQHCs (n = 100) | CBOs (n = 103) | IHS | Tribal | UIO | Pharmacies (n = 103) | Total (n = 507)
Eligible survey completes | 40 | 31 | 39 | 0 | 19 | 4 | 31 | 164
Ineligibles | 4 | 3 | 9 | 1 | 6 | 0 | 9 | 32
Refusals | 0 | 0 | 4 | 0 | 1 | 0 | 3 | 8
Incompletes | 57 | 66 | 51 | 10 | 53 | 6 | 60 | 302
Initial invitations | 101 | 100 | 103 | 11 | 79 | 10 | 103 | 507
Eligible sample | 97 | 97 | 94 | 10 | 73 | 10 | 94 | 475
Response rate | 41% | 32% | 41% | 0% | 26% | 40% | 33% | 35%

Note: Ineligibles included organizations that are no longer in operation, are a duplicate of another organization in the sample, or did not provide COVID19 testing, vaccinations, or information about testing/vaccination. Most ineligible respondents were a duplicate of another already in the sample or no longer in operation. The overall response rate across I/T/U facilities was 25%.

CBO = community-based organization; FQHC = Federally Qualified Health Center; IHS = Indian Health Services; I/T/U = Indian Health Service, tribal, and Urban Indian Organization; LHD = local health department; UIO = Urban Indian Organization.

## C Analysis methods

### 1 Descriptive analyses

All respondents that reported using at least one strategy to deliver or promote COVID-19 testing or vaccination services were included in the analysis. Those respondents may not have completed other questions, such as questions about sources of funding or partnerships. Moreover, some respondents did not answer all questions. Accordingly, the sample frequencies and denominators for reported proportions vary throughout this report depending on the number of respondents that answered the specific survey question(s). Each survey question had a response rate ranging from 91% to 100%. We used R to conduct all quantitative analyses.

For each survey question, we calculated the number and proportion of respondents that selected each response option. Most survey questions allowed respondents to select all response options that applied to them (for example, they could select all the strategies they used to promote or deliver COVID-19 testing). The proportion statistics in most exhibits therefore sum to more than 100% because respondents could select multiple options. When appropriate, we calculated the mean, standard deviation, and range to summarize the number of distinct options selected. We stratified most analyses on organization type and present findings disaggregated by respondents from LHDs, FQHCs, CBOs, T/U facilities, and pharmacies. Because of relatively small sample sizes, we highlight differences in item response rate among certain organization types only if they differ from the overall rate by at least 10 percentage points.

We also stratified some survey questions by responses to other questions (for example, in Sections II.B.2 and III.B.2, in which we stratify strategies on populations of focus). As described in these sections, we were unable to determine with certainty which strategies respondents used to help specific populations of focus. We therefore analyzed the most common testing and vaccination strategies among respondents serving each population of focus. First, we assessed the strategies reported among respondents focusing on a specific population. For example, among all 126 respondents serving older adults, we calculated the proportion that reported using each strategy. Next, we ranked the strategies in order of how commonly they were reported among respondents focusing on each population. In addition, we explored whether certain strategies were more commonly reported (by more than 10%) among respondents serving specific populations of focus (in contrast to how commonly reported they were overall). We calculated these differences and reported examples in Sections II.B.2 and III.B.2. (Full results are available upon request.)

### 2 Hierarchical cluster analysis

To assess whether respondents typically used certain strategies in combination, we performed a complete-linkage agglomerative hierarchical cluster analysis of responses to question 2 and question 9 for testing and vaccination respondents, respectively. Agglomerative hierarchical clustering seeks to cluster respondents by iteratively combining respondents with other respondents into clusters based on the similarity of their responses to the question. Between two respondents, their similarity is measured directly based on how many strategies they both used or both didn’t use. After there are already clusters of respondents, complete-linkage defines how clusters of respondents are compared to continue the iterative combining process. Complete-linkage measures the similarity between clusters based on the largest distance between any pair of respondents where one respondent was selected from each cluster. The clusters that are closest together out of all possible cluster pairings are the next to be combined, and so on.

We then evaluated the quality of clusterings using average silhouette width, a metric that considers both cluster cohesion and separation for each cluster in the clustering (Rouseeuw 1987). Average silhouette width is a metric between −1 and 1 that compares the similarity of respondents within clusters and between cluster, where values closer to 1 indicate that the clustering truly separates respondents into distinct identifiable groups, and lower values indicate less distinction between clusters (Exhibit VI.5). We interpret average silhouette width using thresholds from the literature (Kauffman and Rouseeuw 1990).

Exhibit VI.5 Interpretation of average silhouette width values in hierarchical cluster analysis

Value | Interpretation
0.71 to 1.00 | Strong structure
0.51 to 0.70 | Reasonable structure
0.26 to 0.50 | Weak or artificial structure
≤ 0.25 | No structure

We further investigated the most promising clusterings by average silhouette width using descriptive statistics. Manually investigating the clusterings that way allowed us to directly assess the cohesion of the clusters and potentially dissect themes that may have led to their formation. Ideally, this process would have either directly yielded identifiable cluster profiles, such as “focused on strategies that created distribution hubs” or “focused on strategies that shortened or eliminated commute time to receive services,” or pointed us in a new direction. For example, if one cluster had a clearly identifiable profile or some of the data were severely skewed, a slight change in methods could have enabled us to boost interpretability of the other clusters and raise the overall value of the clustering. But even through manual investigation of the most promising clusterings, we were not able to discover meaningful profile themes for developed clusters or hidden data constructs. This is not a surprise because the majority of the average silhouette widths of our clusterings were less than 0.25, which made the possibility of meaningful profile presence very low. All of our average silhouette widths across clusterings, including sensitivity checks, were less than or equal to 0.33 for clusterings of three or more clusters. We also investigated whether clusters were visible after stratifying strategies by organization type. One could imagine that sufficient overlap among all respondents could lead to a “cloud” of respondents that was difficult to separate but that divides well after applying a logical filter, such as organization type. For this analysis, we separated the data into one bucket per organization type and applied the clustering methodology to each bucket individually. That did not yield more promising results, reflecting that meaningful clusters within organization type were not obfuscated by clustering with all of the respondents together.

We also used the clustering analysis strategy to investigate organization archetypes, or whether organizations of different types typically used certain strategies for certain populations of focus. Using similar logic, it is possible that giving the clustering more information to work with (two questions plus organization type) could lead to meaningful clusterings that were obfuscated when analyzing the strategies alone. For this analysis, we operationalized organization type for clustering by creating a dichotomous variable for each type to include with the question response data. We also ran the analysis for strategy and population of focus, stratified on organization type. The additional information did not yield any more promising results.

Finally, we performed a sensitivity test of these results using an average-linkage agglomerative hierarchical clustering method instead of complete-linkage. Average-linkage defines the distance between clusters as the average distance between all pairs of respondents where one respondent was selected from each cluster. As a result, it may create different clusters at each iteration of the algorithm such that the overall clustering looks different than when using complete-linkage clustering. This sensitivity test showed that our lack of results remained even when a substantial change to the underlying clustering methodology was applied and minimizes concern that misspecification bias is the reason for the non-result.

### 3 Qualitative analysis of open-ended responses

To identify themes that emerged from open-ended survey questions (3b, 6b, 10b, 13b, 17b, 25), we used an inductive thematic coding approach. That is, we reviewed responses to identify themes that were unique from categorical responses already identified by the respondent in leading questions. We then summarized these unique themes for each question. We used Microsoft Excel to conduct all thematic analyses.

We report these findings in Sections II.A.3 and III.A.3 and in call-out boxes in other sections. When we describe qualitative themes, we use quasi-quantitative terms to give the reader a sense of proportion or how many respondents made statements supporting the theme. Typically, we use “a few” to denote two to four, “some” to denote less than half but more than a few, “many” for more than half but less than an overwhelming majority, and “most” if there was a clear or overwhelming majority.

We reviewed all “Other, specify” responses and coded them to existing answer choices when necessary. Responses were left as “Other” if they did not fit into an existing category. No new response codes were created because of this review (that is, we did not observe significant numbers of “Other, specify” responses that we could group together into a new code representing a frequent response). This suggests that our list of response options, which we developed in collaboration with ASPE and OASH based on an environmental scan of published COVID-19 testing and vaccination strategies, was complete enough to reflect most of the strategies respondents used.

## D Limitations

As noted, findings do not generalize to all organizations of a given type included in this study or to other organizations within survey states. The survey was not intended to be representative but rather exploratory. We do not have respondents of each organization type in each survey state, and the response rate of 35 percent was lower than typical response rates for surveys where there is an existing organizational relationship with respondents (for example, surveys of an organization’s grantees or intervention participants, which have a greater incentive or even an obligation to respond). Because the response rate is 35 percent, there is also the potential for nonresponse bias resulting from systematic differences between respondents and nonrespondents. However, we do not have information about characteristics of sampled organizations, such as size or level of experience, that would enable us to assess differences between responding and nonresponding organizations. The response rate across organization type is relatively uniform, except for I/T/U facilities. Because no Indian Health Services facilities responded to the survey, we do not know what Indian Health Services facilities did or think, and results for T/U facilities do not extend to Indian Health Services facilities.

The survey asked about testing and vaccination services for populations at disproportionate risk of COVID-19 or related adverse outcomes (see the instrument in the Appendix), although it is also possible that respondents described approaches used more broadly, including to serve other populations they worked with, when they responded to survey questions.

10 The Partnering for Vaccine Equity program provides funding and support to national, state, local, and community-level partners that are prioritizing equity in vaccination access and uptake for those groups that experience disparities in immunization, with a particular focus on racial and ethnic communities. This program has awarded 250 grants to CBOs. See https://web.archive.org/web/20240518223224/https:/www.cdc.gov/vaccines/health-equity/index.html.

11 The Rockefeller initiative invested in hyperlocal community-led programs to improve vaccination access and accurate information for communities that identify as Black, Latinx, Indigenous, and people of color. See https://www.rockefellerfoundation.org/covid-19-response/creating-vaccine-equity/.

12 As part of the American Rescue Plan, the U.S. Department of Health and Human Services and Health Resources and Services Administration have awarded grants to develop and support a community-based workforce that will engage in locally tailored efforts to build vaccine confidence and bolster COVID-19 vaccinations in underserved communities. See https://www.hrsa.gov/coronavirus/community-based-outreach.