# V Implications for Site Visits

Findings from this survey provide an overview of the range of strategies that respondents used to promote or provide COVID-19 testing and vaccination to communities with disproportionate risks during the first three and a half years of the COVID-19 pandemic. The survey findings will provide helpful context for the detailed information we collect through site visits, and they will give site visit interviewers background information that will enhance their use of the discussion guides. The findings also point to several information gaps that we may be able to address through qualitative interviews. For example, the survey results showed that many organizations used multiple strategies to deliver services, but it could not determine whether these strategies were used concurrently, sequentially, or both over the three-year study period, and it could not specifically tie them to certain populations. In the site visit interviews, we will be able to learn about how strategies or programs changed over time, and what they did to help specific populations.

As we note in the site visit program selection memo, the survey has suggested fewer organizations to select for site visits than we initially expected, for a few reasons. First, many survey respondents did not provide enough information describing which strategies worked well to help us confidently select them for further research that will yield new, unique, or promising practices for the field. Second, among those that provided qualitative information, many were not in the pre-selected site visit states. Lastly, a higher-than-expected number of survey respondents (36%) indicated they are not willing to be contacted for a telephone interview. The survey did, however, make several contributions to the preliminary list of site visit programs, and this is a valuable starting point for conversations with public health leaders about programs or organizations that would be valuable to visit.