# IV Information to Support Planning and Evaluation

This section describes the sources of information that respondents used to plan their COVID-19 vaccination and testing strategies and the metrics respondents used to assess their success. Questions in this section were asked of all survey respondents, whether their focus was on vaccination or testing.

Key findings

- Most respondents reported using information from multiple sources to develop their COVID-19 testing or vaccination strategies. LHDs, FQHCs, and CBOs used the most sources whereas pharmacies used the fewest. The most commonly reported sources of information for planning were community guides, community-level data (about COVID-19 disease, testing, or vaccination rates), and information or best practices from federal programs.
- Respondents typically assessed their success by looking at outputs rather than outcomes. Commonly reported outputs included numbers of vaccine doses and tests delivered, adherence to CDC guidelines, and participants’ satisfaction. Organizations that did track outcomes tended to focus on vaccination rates more commonly that testing rates.

## A Information to support planning for COVID-19 vaccination and testing strategies

Exhibit IV.1 describes the sources of information that survey respondents used to plan their strategies. We present results for all organization types, whether they provided vaccination or testing; this survey question was asked only once of all respondents, whether they worked on testing, vaccination, or both. We also summarize the number of different sources of information reported among respondents to this question. The top three most commonly reported sources of information for each organization type are shaded.

Exhibit IV.1 Sources of information used to develop COVID-19 testing or vaccination strategies

Information sources | LHDs (n = 40) | FQHCs (n = 31) | CBOs (n = 31) | T/U facilities (n = 18) | Pharmacies (n = 30) | Overall (n = 150)
Community guides, such as the Centers for Disease Control and Prevention’s (CDC’s) Community Guide | 75%^*^ | 96.8%^*^ | 83.9%^*^ | 83.3%^*^ | 83.3%^*^ | 84%^*^
Community-level data about COVID-19 disease, testing, or vaccination rates | 85.0%^*^ | 80.6%^*^ | 90.3%^*^ | 83.3%^*^ | 70.0%^*^ | 82.0%^*^
Information or best practices from federal programs such as CDC’s Partnering for Vaccine Equity program or the National Institutes of Health’s RADx-UP program | 57.5% | 67.7%^*^ | 54.8% | 77.8%^*^ | 60.0%^*^ | 62.0%^*^
Internal staff expertise or experience | 77.5%^*^ | 61.3% | 45.2% | 55.6% | 30.0% | 55.3%
Learning from peers at other organizations | 62.5% | 51.6% | 58.1% | 38.9% | 36.7% | 51.3%
Guidance, information, or best practices from associations (for example, from the Association for State and Territorial Health Officials or the National Association of County and City Health Officials) | 47.5% | 38.7% | 64.5% | 44.4% | 50.0% | 49.3%
Input from community groups or community members | 60.0% | 41.9% | 77.4%^*^ | 33.3% | 13.3% | 47.3%
Guidance (for example, from CDC for grantees or information in notices of funding opportunity) | 45.0% | 51.6% | 51.6% | 22.2% | 13.3% | 38.7%
Communities of practice such as the Rockefeller Foundation’s Equity-First Vaccine Initiative or CDC’s Partnering for Vaccine Equity program | 20.0% | 22.6% | 29.0% | 11.1% | 16.7% | 20.7%
Other information source | 0.0% | 3.2% | 0.0% | 0.0% | 0.0% | 0.7%
Number of different sources of information reported
Min, Max | 1, 9 | 1, 9 | 1, 9 | 2, 9 | 1, 8 | 1, 9
Mean (SD) | 5.3 (2.2) | 5.2 (2.2) | 5.6 (2.1) | 4.5 (2.2) | 3.7 (2.0) | 4.9 (2.2)

* Indicates the top three most commonly reported sources of information for each organization type.

Note: This question was asked of all survey respondents and results are not disaggregated by testing versus vaccination. Percentages sum to more than 100% because survey respondents were prompted to select all that apply. Ns for each organization type reflect only those that answered each question. The item response rate for this question was lower among CBO and T/U respondents compared to other organization types (79% and 78%, respectively, compared to 91% overall).

CBO = community-based organization; FQHC = Federally Qualified Health Center; T/U = Tribal and Urban Indian Organization; LHD = local health department.

Most respondents reported using information from multiple sources, but some organization types used more data than others. On average, respondents referenced five different information sources when developing COVID-19 vaccination or testing strategies, with a range of one to nine of the possible 10 options. LHDs, FQHCs, and CBOs referenced the most sources (about five to six on average), whereas pharmacies referenced the fewest (fewer than four on average).

Community guides (such as from the Centers for Disease Control and Prevention [CDC]), community-level data (about COVID-19 disease, testing, or vaccination rates), and information or best practices from federal programs (such as CDC’S P4VE or RADx initiative) were most commonly used for planning, suggesting that these information sources are broadly useful for organizations with varying scopes and missions. In particular, FQHCs commonly reported using community guides (97%), CBOs frequently leveraged community-level data (90%), and T/U facilities commonly referenced best practices information (78%).

Use of grantee guidance from funders or communities of practice for planning was less common and depended on the organization type. Grantee guidance (for example, from CDC for grantees or information in notices of funding opportunity) was more common among LHDs, FQHCs, and CBOs (45% to 52%) than among T/U facilities (22%) and pharmacies (13%). Relatively few respondents overall reported using information from communities of practice such as the Rockefeller Foundation’s Equity-First Vaccine Initiative or CDC’s P4VE to plan testing or vaccination strategies (ranging from 29% for CBOs to 11% for T/U facilities).

## B Information to support COVID-19 testing and vaccination evaluation

Exhibit IV.2 Information used to evaluate how well testing or vaccination strategies worked, by organization type

Metrics | LHD (n = 40) | FQHC (n = 31) | CBO (n = 31) | ITU (n = 18) | CP (n = 30) | Overall (n = 150)
Number of vaccine doses delivered | 85.0% | 90.3% | 45.2% | 61.1% | 73.3% | 72.7%
Vaccination rates^*^ | 92.5% | 80.6% | 51.6% | 61.1% | 33.3% | 66.0%
Number of tests delivered | 57.5% | 80.6% | 41.9% | 61.1% | 46.7% | 57.3%
Adherence to CDC or other guidelines | 60.0% | 61.3% | 35.5% | 61.1% | 40.0% | 51.3%
Participants’ satisfaction | 47.5% | 29.0% | 38.7% | 44.4% | 60.0% | 44.0%
Testing rates^*^ | 65.0% | 67.7% | 9.7% | 50.0% | 23.3% | 44.0%
Outputs of outreach and education strategies, such as number of phone calls made or user engagement with social media | 47.5% | 22.6% | 71.0% | 27.8% | 23.3% | 40.0%
Test positivity rate^*^ | 65.0% | 61.3% | 9.7% | 44.4% | 13.3% | 40.0%
Reach of outreach and education strategies, such as geographic reach or people contacted | 52.5% | 25.8% | 71.0% | 22.2% | 6.7% | 38.0%
Geographic reach of testing services, such as number of counties served or homes visited | 47.5% | 19.4% | 29.0% | 16.7% | 10.0% | 26.7%
Assessment of the organization’s partnerships at community, local, state, or federal levels | 32.5% | 19.4% | 35.5% | 16.7% | 10.0% | 24.0%
Qualitative assessment based on program or community knowledge (not based on metrics) | 30.0% | 12.9% | 35.5% | 11.1% | 20.0% | 23.3%
Measured improvements in knowledge or attitudes about COVID-19 testing or vaccines^*^ | 25.0% | 16.1% | 32.3% | 11.1% | 20.0% | 22.0%
Other (please specify) | 0.0% | 6.5% | 0.0% | 0.0% | 0.0% | 1.3%
We did not evaluate our testing and vaccination strategies | 5.0% | 0.0% | 3.2% | 5.6% | 3.3% | 3.3%

* Indicates outcome metrics.

Note: Percentages sum to more than 100% because survey respondents were prompted to select all that apply.

Ns include only those that answered this question. The item response rate for this question was lower among CBO and T/U respondents compared to other organization types (79% and 78%, respectively, compared to 91% overall). Responses reflect metrics used to assess testing and vaccination because this question was asked of all survey respondents (not separately of those working on testing or vaccination).

CBO = community-based organization; FQHC = Federally Qualified Health Center; T/U = Tribal and Urban Indian Organization; LHD = local health department.

Exhibit IV.2 shows the metrics that respondents used to assess the effectiveness of their strategies, by organization type and ordered by how commonly reported each metric was overall. Shaded rows denote outcome metrics, and all other rows are output metrics. Program outputs refer to measures of the quantity and quality of program activities and service delivery, whereas program outcomes are measures of changes among program recipients, such as changes to COVID-19 testing and vaccination awareness and confidence and changes in testing and vaccination rates. As we note in Section I, most respondents worked on testing and vaccination, either in parallel or at various points in the pandemic, and this survey question was asked only once of all respondents, whether they worked on testing, vaccination, or both.

Respondent insights: metrics used to identify and assess implementation and evaluation outcomes

When asked to elaborate on the metrics they used to identify and assess implementation and evaluation outcomes, many respondents confirmed that they looked at testing and vaccination rates, positivity rates, and customer satisfaction to assess how well their strategies worked. A few respondents said they have population health departments or academic partners to specifically handle program evaluations. A few organizations also noted using geographic mapping to evaluate their strategies.

Nearly all respondents reported assessing the success of their testing and vaccination strategies. Of the organizations working to deliver COVID-19 testing and vaccination that responded to this survey question, about 97% used at least one of the metrics in Exhibit IV.2.

Outputs were more frequently used than outcomes, consistent with findings from our environmental scan. Outputs refer to measures of the quantity and quality of organizational activities and service delivery, and outcomes are measures of changes among service recipients, such as changes to COVID-19 testing and vaccination awareness and confidence and changes in testing and vaccination rates. For example, 73% of respondents monitored the number of vaccines administered, and 57% monitored the number of tests delivered. Many respondents also reported monitoring the outputs of educational strategies (such as the number of phone calls made) or the reach of those outreach activities (about 40% for both metrics, overall). Other commonly monitored outputs included adherence to CDC guidelines (most commonly reported among FQHCs and T/U facilities) and participant satisfaction (most commonly reported among pharmacy respondents).

Respondents across all organization types commonly reported monitoring vaccination outcomes, whereas only LHDs and FQHCs commonly monitored testing outcomes. Vaccination rates were the most commonly reported outcome metric, reported by 72% of overall respondents. Outcomes related to testing, including testing rates or test positivity rates, were less common overall and among most organization types. The exception was LHDs, with 65% of respondents reporting monitoring these testing outcomes.

Respondents from organizations that delivered both testing and vaccination services tended to report more metrics overall than those that worked on testing only or vaccination only (not shown). For example, the use of certain metrics was much lower for organizations offering testing only, without a vaccination component. It is possible that organizations offering vaccination and testing services had more resources for service delivery as well as monitoring and evaluation activities.