# III Findings on COVID-19 Vaccination

## A Strategies respondents used to deliver COVID-19 vaccinations

This section describes strategies used to promote or provide COVID-19 vaccinations for populations at disproportionate risk of COVID-19 or related adverse outcomes. As with testing, the survey asked about vaccination services for populations at disproportionate risk of COVID-19 or related adverse outcomes (see the instrument in the appendix), although it is also possible that respondents generalized to other populations they worked with when they responded to survey questions. We also describe the most prevalent vaccination strategies, summarize respondents’ perceptions of which strategies were effective, and describe the partnerships that organizations engaged to deliver vaccination strategies.

Key findings

- As with testing, many respondents that promoted or provided vaccinations used more than one strategy, and some used as many as 15. On average, LHDs reported using the most strategies and pharmacies the least. Because respondents summarized their organizations’ experiences over more than three years, it is not clear from the survey data which strategies they used simultaneously versus sequentially as the pandemic unfolded.
- Community-based vaccination clinics and events were used more than any other strategy by all organization types. As with testing, partnering with organizations or people trusted by the community was the second most-commonly reported strategy; providing vaccination services outside of typical business hours was another common vaccination strategy. Holding mass vaccination clinics was more common than mass testing, whereas conducting educational outreach about vaccination was less common than educational outreach for testing.
- As with testing, partnerships were common across all organization types, particularly partnerships with government offices, CBOs, and medical providers. LHDs tended to use partnerships the most, and with the greatest range of partners, while pharmacies partnered the least. Partnerships with businesses, faith-based organizations, and educational institutions were less common overall, with a few exceptions.
- As with testing, we did not find evidence that strategies typically fell into certain clusters or combinations.

### 1 COVID-19 vaccination strategies

Exhibit III.1 shows the number of different vaccination strategies respondents reported using to promote or administer COVID-19 vaccinations to communities at disproportionate risk.

Exhibit III.1 Number of different vaccination strategies used by organizations

Number of different strategies reported | LHDs (n = 39) | FQHCs (n = 30) | CBOs (n = 30) | T/U facilities (n = 18) | Pharmacies (n = 29) | Overall (n = 146)
Min, Max | 1, 15 | 1, 14 | 2, 15 | 2, 11 | 1, 13 | 1, 15
Mean (SD) | 9 (4) | 8 (3) | 7 (4) | 7 (3) | 6 (3) | 7 (4)

CBO = community-based organization; FQHC = Federally Qualified Health Center; T/U = Tribal and Urban Indian Organization; LHD = local health department.

Similar to testing, most respondents reported that that their organization used multiple vaccination strategies, up to 15 out of a possible 18. The median number of vaccination strategies for each organization type was also very similar to the median numbers of testing strategies. As noted in the testing section, however, it is not clear which strategies organizations used simultaneously versus sequentially over the pandemic period. The average number of vaccination strategies used was seven. LHDs used the most strategies, with an average of nine, and pharmacies used the least, with an average of six. Exhibit III.2 shows this information graphically. These findings might reflect that LHDs typically offer a wider range of services overall than pharmacies.

Exhibit III.2 Box and whisker plot of different vaccination strategies reported by respondents

Note: Vertical lines in the box and whisker plot (the whiskers) show the range of the number of vaccination strategies reported by each organization type. If the range includes outliers, such as for pharmacies, they are represented by dots. The horizontal lines within boxes show the median number, and the height of the boxes denotes the middle two quartiles (in which around 50% of the observations fall for each organization type).

CBO = community-based organization; FQHC = Federally Qualified Health Center; T/U = Tribal and Urban Indian Organization; LHD = local health department.

Exhibit III.2 is a box and whisker plot showing the median and range of the number of different vaccination strategies reported by the surveyed organizations. Local health departments and federally qualified health centers reported the most reported strategies.

Exhibit III.3 shows the proportion of each organization type that reported using different strategies to promote or deliver COVID-19 vaccinations, in order of how commonly they were reported overall. The top five most commonly reported strategies for each organization type are shaded.

Exhibit III.3 Vaccination strategies used by organizations that responded to the survey

Strategies | LHDs (n = 39) | FQHCs (n = 30) | CBOs (n = 30) | T/U facilities (n = 18) | Pharmacies (n = 29) | Overall (n = 146)
Held community-based vaccination clinics such as at a church, mall, library, community center, school, public housing, or shelter or events | 89.7%^*^ | 80.0%^*^ | 76.7%^*^ | 77.8%^*^ | 65.5%^*^ | 78.8%^*^
Partnered with organizations such as food banks, churches, or schools or people trusted by community such as religious leaders, school staff, or community health workers | 76.9%^*^ | 73.3%^*^ | 90.0%^*^ | 55.6%^*^ | 37.9% | 68.5%^*^
Provided vaccination services outside of typical business hours or offered walk-in appointments | 89.7%^*^ | 76.7%^*^ | 26.7% | 61.1%^*^ | 72.4%^*^ | 67.1%^*^
Held mass vaccination clinics, sometimes called mega-vaccination sites, intended to provide a high volume of vaccines in locations such as stadiums or parking lots or events | 87.2%^*^ | 70.0%^*^ | 43.3% | 72.2%^*^ | 51.7%^*^ | 65.8%^*^
Conducted educational outreach or campaigns using communication tools or media such as phone calls, text messages, emails, social media, or mass media (TV or radio) | 79.5%^*^ | 60.0% | 80.0%^*^ | 66.7%^*^ | 37.9% | 65.8%^*^
Paired COVID-19 vaccination services with routine vaccination services | 69.2% | 66.7% | 23.3% | 44.4% | 72.4%^*^ | 56.8%
Paired vaccination services with other medical or social services | 48.7% | 80.0%^*^ | 40.0% | 38.9% | 37.9% | 50.0%
Delivered messaging or provided services in multiple languages | 61.5% | 53.3% | 60.0%^*^ | 16.7% | 24.1% | 46.6%
Provided mobile vaccination services such as with a van | 59.0% | 46.7% | 43.3% | 22.2% | 34.5% | 43.8%
Held in-person educational events such as a town hall | 30.8% | 30.0% | 53.3%^*^ | 38.9% | 20.7% | 34.2%
Provided in-home or door-to-door vaccination services | 64.1% | 10.0% | 10.0% | 27.8% | 44.8%^*^ | 33.6%
Trained partners on how to provide vaccines or outreach, such as staff in provider organizations | 41.0% | 23.3% | 30.0% | 16.7% | 20.7% | 28.1%
Gave out financial incentives such as cash, gift cards, vouchers, or coupons | 33.3% | 20.0% | 40.0% | 44.4% | 3.4% | 27.4%
Eliminated identification or documentation requirements to reach people who might be undocumented or uninsured | 38.5% | 20.0% | 30.0% | 16.7% | 20.7% | 26.7%
Provided transportation services to vaccination sites | 17.9% | 30.0% | 23.3% | 50.0% | 3.4% | 22.6%
Gave out non-financial incentives such as food or merchandise | 15.4% | 13.3% | 40.0% | 16.7% | 3.4% | 17.8%
Other | 0.0% | 0.0% | 10.0% | 5.6% | 6.9% | 4.1%

* Indicates the top five most commonly reported strategies for each organization type.

Note: Percentages sum to more than 100% because survey respondents were prompted to select all that apply.

CBO = community-based organization; FQHC = Federally Qualified Health Center; T/U = Tribal and Urban Indian Organization; LHD = local health department.

The five most commonly reported strategies were largely consistent across organization types. Similar to testing strategies, partnering with other organizations was the second most common vaccination strategy overall. Although some testing and vaccination strategies are inherently different, it is unsurprising that we see parallels in the responses to these and other survey questions because most organizations responding to the survey completed the sections on both testing and vaccination. Holding mass vaccination clinics was more common than mass testing clinics (66% for vaccination versus 52% for testing), whereas conducting educational outreach about vaccination was less common than educational outreach for testing (66% for vaccination versus 77% for testing). The five most commonly reported vaccination strategies were:

1. Offering community-based vaccination clinics (79% of all respondents). This was in the top five most common strategies for all organization types and was most prevalent among LHDs (90%). This was also a top five strategy among testing respondents.
2. Partnering with organizations or people trusted by the community (69% overall) was among the top five strategies for all organization types except pharmacies. CBOs most commonly reported this strategy (90%).
3. Providing vaccination services outside of typical business hours or offering walk-in appointments (67% overall) was in the top five for all organization types except CBOs. LHDs most frequently reported this strategy (90%).
4. Mass vaccination clinics (66% overall) was a top five strategy for all organization types except CBOs. LHDs reported using this strategy most (87%).
5. Conducting educational outreach or campaigns using communication tools or media (66% overall) was a top five strategy for CBOs (80%), LHDs (80%), and T/U facilities (67%).

Some strategies were reported more commonly by certain organization types. For example, pairing COVID-19 vaccinations with routine vaccinations was more commonly reported by LHD, FQHC, and pharmacy respondents (each about 70%) and less commonly by CBOs (23%) and T/U facilities (44%). Delivering messaging or providing services in multiple languages was reported more often by LHD (62%), FQHC (53%), and CBO (60%) respondents (compared with 24% and 17% among pharmacies and T/U facilities, respectively). Providing in-home or door-to-door vaccination services was most commonly reported among LHD respondents (64%) and least commonly by FQHCs and CBOs (10% each). Finally, the strategies more commonly reported by T/U facilities than other organization types included giving out financial incentives (44% versus 27% overall) and providing transportation services to vaccination sites (50% versus 23% overall).

As with testing, we did not see meaningful clusters of activities among vaccination respondents. We conducted a hierarchical cluster analysis to assess whether organizations tend to group certain strategies, but we did not find clusters, likely for the same reasons noted in the testing section. We also did not observe meaningful archetypes of organizations of different types that tended to deliver certain strategies for certain populations.

### 2 Partnerships for delivering COVID-19 vaccination

Exhibit III.4 shows the types of organizational partnerships that supported vaccination strategies, in order of how commonly they were reported overall, and stratified by organization type. (Partnerships were also a survey response option for vaccination strategies (Exhibit III.3); this exhibit shows responses to a separate question about partnerships that helped respondents carry out any or all their vaccination strategies.). The top three most commonly reported partnerships for each organization type are shaded (or top four when there was a tie).

Exhibit III.4 Types of partnerships used to deliver vaccination services, by organization type

Partner organizations | LHDs (n = 39) | FQHCs (n = 30) | CBOs (n = 27) | T/U facilities (n = 16) | Pharmacies (n = 28) | Overall (n = 140)
Local, state, or federal government offices or programs | 84.6%^*^ | 93.3%^*^ | 88.9%^*^ | 87.5%^*^ | 57.1%^*^ | 82.1%^*^
Community-based organizations | 79.5%^*^ | 83.3%^*^ | 85.2%^*^ | 50.0%^*^ | 42.9% | 70.7%^*^
Medical providers or facilities | 82.1%^*^ | 33.3% | 85.2%^*^ | 50.0%^*^ | 64.3%^*^ | 65.0%^*^
Businesses, employers, or workplaces | 71.8% | 40.0% | 44.4% | 31.3% | 50.0%^*^ | 50.7%
Faith-based organizations | 66.7% | 53.3%^*^ | 66.7% | 12.5% | 21.4% | 48.6%
Educational institutions | 79.5% | 50.0% | 40.7% | 25.0% | 17.9% | 47.1%
We did not partner with other organizations | 2.6% | 0.0% | 0.0% | 0.0% | 7.1% | 2.1%

* Indicates the top three most commonly reported partnerships for each organization type (or top four when there was a tie).

Note: Percentages sum to more than 100% because survey respondents were prompted to select all that apply. Ns for each organization type reflect only those that answered each question.

CBO = community-based organization; FQHC = Federally Qualified Health Center; T/U = Tribal and Urban Indian Organization; LHD = local health department.

Nearly all (98%) respondents worked in partnership with other organizations to deliver vaccination services. Vaccination partnerships were most common among FQHC, CBO, and T/U respondents, all of which reported engaging in at least one form of partnership. As with testing, LHD and CBO respondents reported the greatest number of different partnership types (five and four on average, respectively, out of a possible six, results not shown).

As with testing, pharmacies were the organization type that least commonly reported engaging in partnerships. In all, 7% of the pharmacy respondents who answered this survey question said they did not engage in any partnerships to promote or deliver vaccinations. This proportion is lower than for testing, where 29% of pharmacy respondents said they did not partner to promote or deliver testing services. When pharmacies did partner with other organizations, they most commonly did so with medical providers or facilities (64%), which differs from testing.

Exhibit III.5 shows the proportion of vaccination respondents that reported engaging in each type of partnership ordered by how commonly they were reported overall. The bars represent the proportion of respondents of each organization type reporting each type of partnership.

Exhibit III.5 Types of organizations that survey respondents reported partnering with to deliver vaccination services

CBO = community-based organization; FQHC = Federally Qualified Health Center; T/U = Tribal and Urban Indian Organization; LHD = local health department.

Exhibit III.5 is a bar graph showing the types of partners that responding organizations engaged to deliver vaccination services. Local health departments and federally qualified health centers engaged the most partners.

Exhibit III.5 shows that, as with testing, partnerships with government offices or programs, CBOs, and medical providers and facilities were more common than partnerships with the other three types of partners, but there was variation by respondent type. This variation was similar to testing, but a noticeably smaller proportion of FQHCs reported partnering with medical providers to deliver vaccination (33%) than to deliver testing (55%). In contrast to testing, no vaccination respondents reported engaging in “other” types of partnerships.

Exhibit III.5 also shows that small proportions of T/U facilities and pharmacies partnered with faith-based organizations and educational institutions relative to other organizations. In contrast, there were roughly equal proportions of LHDs that partnered with all partner types, including with faith-based organizations and educational institutions.

### 3 Perceived effectiveness of COVID-19 vaccination strategies

When asked about most effective vaccination strategies, respondents provided free text answers that were similar to answers about effective testing strategies. As with testing, multiple respondents noted that their organizations’ most effective vaccination strategies were those that reduced time, transportation, and child care barriers by increasing convenience and access. Successful strategies also made vaccination more appealing through activities or events, reached many people at once, and went directly to individuals, including at schools and in the workplace. The finding that partnerships with schools were effective appears to contrast with the finding that educational partnerships were less common than other partnership types; this apparent contrast could be due to the fact that many schools were closed for part of the pandemic but partnerships were effective when they were possible. It also suggests, however, that additional partnerships with educational institutions could pay dividends. Some respondents made vaccinations available during patient encounters, including when picking up prescriptions and medical supplies (such as clean syringes) or getting other vaccines.

As with testing, many respondents saw the use of local partners to build trust as essential to increasing vaccinations. Partners helped to destigmatize getting the vaccination by providing culturally appropriate education and information. Community health navigators and workers also helped to connect organizations with community members.

Other effective but less common strategies included providing vaccinations and vaccine information at non-traditional settings, such as bars and breweries; providing vouchers for ride services; and allowing public transport vehicles at vaccine drive-thru sites. One respondent described the provision of motivational interviewing training to vaccine providers as effective. This involved coaching people into making pro-health decisions rather than using fear as motivation.

Many respondents described the need to tailor outreach and service delivery to reach specific populations to ensure that vaccination efforts were effective overall. Respondents described tailoring outreach (such as where, when, and from whom messaging was disseminated) and service delivery to overcome barriers and meet needs for people experiencing homelessness, Hispanic/Latino populations, rural communities, individuals with developmental/intellectual disabilities, vulnerable or historically marginalized populations, public housing residents, and people who are undocumented. For example, one respondent noted: “Speaking with people in their native language and using trusted messengers was key to our success.“

## B Populations of focus for COVID-19 vaccination strategies

Here, we describe the populations and communities that responding organizations focused on when promoting or delivering COVID-19 vaccination services. We also describe patterns between populations of focus and the strategies used by organizations serving certain population groups.

Key findings

- As with testing, FQHCs and LHDs reported the most populations of focus and pharmacies and T/U facilities reported the fewest.
- As with testing, the most commonly reported populations of focus across organization types were older adults and younger adults, and the least reported was incarcerated populations.
- Other common populations of focus differed by organization type. For example, FQHCs tended to focus more on populations in unique or vulnerable housing situations—such as people in multigenerational housing, residents of public housing, people experiencing homelessness or housing insecurity, and residents of shelters—than other organization types.
- Like with testing, the most common vaccination strategies--holding community vaccination clinics or events, partnering with CBOs and community members, expanding hours, and holding mass vaccination events —were commonly reported regardless of population of focus, likely due to their broad scope. Unlike with testing, there was a weaker relationship between specific populations of focus and specific strategies.

### 1 Populations of focus for vaccination strategies

Exhibit III.6 shows the populations of focus among respondents that worked on vaccination in order of how commonly each population was reported overall. As with testing, we shaded the exhibit cells in which at least 75% of respondents among each organization type reported a population of focus. The exhibit also summarizes the total number of different populations of focus that each organization type reported. Note that we cannot determine whether organizations focused on all populations simultaneously or at different points in the pandemic.

Exhibit III.6 Populations of focus, by organization type

Populations of focus | LHDs (n = 39) | FQHCs (n = 30) | CBOs (n = 27) | T/U facilities (n = 18) | Pharmacies (n = 28) | Overall (n = 142)
Older adults older than age 65 | 97.4%^*^ | 100.0%^*^ | 92.6%^*^ | 94.4%^*^ | 100.0%^*^ | 97.2%^*^
Young adults ages 18 to 24 years old | 87.2%^*^ | 86.7%^*^ | 96.3%^*^ | 83.3%^*^ | 82.1%^*^ | 87.3%^*^
People or communities with low income | 84.6%^*^ | 96.7%^*^ | 88.9%^*^ | 55.6% | 67.9% | 81.0%^*^
People with specific underlying medical conditions | 89.7%^*^ | 90.0%^*^ | 51.9% | 83.3%^*^ | 71.4% | 78.2%^*^
Frontline workers or other people at increased risk of COVID-19 because of their occupation such as migratory and seasonal agricultural workers | 87.2%^*^ | 80.0%^*^ | 51.9% | 77.8%^*^ | 89.3%^*^ | 78.2%^*^
People without health insurance | 76.9%^*^ | 93.3%^*^ | 66.7% | 50.0% | 78.6%^*^ | 75.4%^*^
Communities in a specific geographic area for example, neighborhoods, wards, or towns, or areas defined by high need | 71.8% | 80.0%^*^ | 85.2%^*^ | 61.1% | 53.6% | 71.1%
Children ages 0 to 17 | 79.5%^*^ | 80.0%^*^ | 66.7% | 72.2% | 42.9% | 69.0%
People with disabilities, for example, physical disabilities, intellectual disabilities, visual impairments | 76.9%^*^ | 80.0%^*^ | 48.1% | 55.6% | 75.0%^*^ | 69.0%
People with limited English proficiency | 71.8% | 83.3%^*^ | 77.8%^*^ | 11.1% | 60.7% | 65.5%
People or communities with low education or literacy | 59.0% | 93.3%^*^ | 74.1% | 27.8% | 57.1% | 64.8%
Hispanic communities | 74.4% | 80.0%^*^ | 77.8%^*^ | 5.6% | 53.6% | 63.4%
Rural communities | 64.1% | 63.3% | 59.3% | 55.6% | 46.4% | 58.5%
Black or African American communities | 59.0% | 73.3% | 66.7% | 11.1% | 50.0% | 55.6%
Immigrant communities, including refugees and people without documentation | 66.7% | 60.0% | 63.0% | 5.6% | 50.0% | 53.5%
People with substance use disorder | 46.2% | 70.0% | 37.0% | 44.4% | 42.9% | 48.6%
People in multigenerational housing | 35.9% | 70.0% | 59.3% | 44.4% | 28.6% | 47.2%
Residents of public housing | 43.6% | 60.0% | 48.1% | 38.9% | 39.3% | 46.5%
American Indian or Alaska Native communities | 38.5% | 46.7% | 37.0% | 88.9%^*^ | 28.6% | 44.4%
People experiencing homelessness or housing insecurity | 48.7% | 63.3% | 51.9% | 22.2% | 17.9% | 43.0%
Residents of nursing homes or long-term care facilities | 64.1% | 26.7% | 22.2% | 16.7% | 53.6% | 40.1%
Lesbian, gay, bisexual, transgender, queer/questioning, intersex, asexual/agender, and two-spirit (LGBTQIA2S+) populations | 35.9% | 63.3% | 40.7% | 22.2% | 21.4% | 38.0%
Residents of shelters | 48.7% | 50.0% | 40.7% | 16.7% | 14.3% | 36.6%
Asian communities | 46.2% | 50.0% | 33.3% | 0.0% | 35.7% | 36.6%
Veterans | 35.9% | 43.3% | 22.2% | 22.2% | 28.6% | 31.7%
Native Hawaiian or other Pacific Islander communities | 35.9% | 40.0% | 22.2% | 5.6% | 25.0% | 28.2%
Incarcerated populations | 41.0% | 20.0% | 3.7% | 5.6% | 0.0% | 16.9%
Number of different populations of focus reported
Min, Max | 1, 27 | 7, 27 | 4, 25 | 1, 25 | 3, 26 | 1, 27
Mean (SD) | 16.7 (7.8) | 18.4 (5.4) | 14.9 (5.9) | 10.8 (6.0) | 13.1 (6.7) | 15. (6.9)

* Indicates table cells in which at least 75% of respondents of each organization type reported a population of focus.

Note: Percentages sum to more than 100% because survey respondents were prompted to select all that apply. Ns for each organization type reflect only those that answered each question.

CBO = community-based organization; FQHC = Federally Qualified Health Center; T/U = Tribal and Urban Indian Organization; LHD = local health department.

As with testing, nearly all vaccination respondents reported serving older adults, most focused on young adults, and few focused on incarcerated populations. Older adults were the most commonly reported population of focus across all organization types except CBOs, and more than 90% of respondents in each organization type reported this population of focus (ranging from 93% to 100%). This is parallel to the finding for testing, reflecting that either most organizations responding to the survey provided both testing and vaccination services and might have done so together or that these organizations simply prioritized one of the most medically at-risk populations at different points in the pandemic. More than 75% of respondents among every organization type reported focusing on adults ages 18 to 24 (87% overall). The least commonly reported population of focus was incarcerated persons (17% overall). Similar to testing, a larger proportion of LHD vaccination respondents reported this population of focus (41%).

Respondent insights: Serving specific communities

The survey data do not reveal which strategies were used to support specific populations of focus, only the proportion of organizations that reported using each strategy, among those focusing on different populations. Yet open-ended responses provide additional context. When asked about their most effective vaccination strategies, respondents noted that developing culturally adapted messaging and engaging local partnerships were particularly useful strategies for serving specific populations, including people experiencing homelessness, Hispanic/Latino populations, rural communities, people with developmental/intellectual disabilities, and people who are undocumented or living in public housing.

Other populations of focus reported by at least 75% of respondents varied by organization type and, similar to testing, largely aligned with each organization type’s typical mission and operations. We present these results in order of the greatest number of different populations of focus each organization type reported to the least.

- FQHCs reported focusing on the greatest number of different populations, in parallel to the finding for testing. FQHC vaccination respondents reported an average of 18 populations of focus. Similar to FQHCs that provided testing services, those that provided vaccinations reported focusing on several groups facing economic insecurity. In contrast to testing, FQHCs also reported focusing on populations in specific housing situations—such as people in multigenerational housing, residents of public housing, and people experiencing homelessness or housing insecurity—to a greater extent than other organization types, with the exception of residents of shelters.
- Like FQHCs, LHDs often reported focusing on people with underlying medical conditions, frontline workers, people without health insurance, children, and people with disabilities. As with testing, LHDs were distinguished from FQHCs by their greater focus on residents of nursing homes (64% versus 27%) and incarcerated populations (41% versus 20%).
- CBOs, like FQHCs, commonly reported focusing on communities in a specific geographic area, people with limited English proficiency, Hispanic populations, and people or communities with low education or literacy. This finding is different from the one in testing, in which the focus on serving people in defined geographic areas was more prevalent among T/U facilities.
- Similar to FQHCs and LHDs, pharmacies focused on frontline workers, people without health insurance, and people with disabilities. Similar to LHDs, pharmacies reported focusing on residents of nursing homes at a higher rate than most other organization types (54% compared with 40% overall). As with testing, pharmacies focused on children less frequently than other organization types (43% compared with 69% overall).
- Unlike testing, T/U facilities reported the fewest populations of focus for vaccination efforts. But like testing, T/U facilities overwhelmingly and unsurprisingly focused on American Indian and Alaskan Native populations (89%) compared with other organization types (44% overall). Similar to FQHCs and LHDs, T/U facilities also focused on people with underlying medical conditions and frontline workers, in addition to children.

### 2 Patterns of strategies used and populations of focus

As with testing, we use this section to describe the most commonly reported vaccination strategies among organizations that reported each population of focus. We do not include the exhibit of results because of its large size.

As with testing, respondents reporting the most common vaccination strategies also reported focusing on a wide range of populations. For example, community-based vaccination clinics was the most commonly reported strategy, reported among 80% of all respondents working to promote or deliver vaccinations, regardless of the population of focus. The next two most-common vaccination strategies, partnering with community organizations and trusted community leaders (68.3%) and providing vaccination services outside of typical business hours or offering walk-in appointments, each were reported by 68% of respondents working on vaccination. These strategies were commonly reported by organizations focused on people of all ages, people with limited English proficiency, residents of nursing homes and public housing, rural communities, and more. The high frequency with which these strategies were reported among respondents serving different populations suggests that they may have been widely applicable and possibly essential for reaching diverse populations with different needs and circumstances.

Some strategies were reported substantially more often (greater than 10%) among respondents focusing on specific populations; however, these relationships were weaker than for testing. For example, the strategy of delivering vaccinations in multiple languages was reported more commonly among organizations that focused on immigrant populations (69%), people with limited English proficiency (66%), and Hispanic people (68%) compared with overall (47%). Yet unlike testing, this strategy was also commonly reported by respondents that focused on Black or African American populations (62%), Asian populations (65%), and Native Hawaiian or other Pacific Islander populations (63%) as well as several other populations of focus such as residents of shelters (73%) and LGBTQI2S+ populations (59%). This finding highlights the fact that we cannot say for sure what strategies were used for which populations of focus; it is possible that the organizations that provided translation services to Hispanic communities also served LGBTQI2S+ populations but not necessarily that the latter group was the recipient of the translation. More research is needed to unpack whether and how different strategies were most relevant and useful for various populations of focus.

As with testing, we did not observe meaningful archetypes, or organizations of certain types that tended to use certain testing strategies for specific populations of focus. Although responding organizations used several different strategies and served many populations, there was no meaningful pattern of combinations of strategies used for specific populations by certain organization types.

## C Barriers to, facilitators of, and funding for COVID-19 vaccination strategies

Here, we share findings on the barriers and facilitators organizations experienced when delivering COVID-19 vaccination services. We also discuss findings on the sources of funding organizations used for vaccination strategies.

Key findings

- As with testing, inner setting challenges were more commonly reported across all organization types with the exception of LHDs. The most commonly reported inner setting challenges were limited staffing, limited time, and limited supplies. Supplies posed less of a challenge for vaccination compared to testing. Certain organization types more commonly faced distinct challenges, such as pharmacies facing time constraints and FQHCs lacking refrigeration, suggesting potential ways to support them in providing vaccination services.
- As with testing, the most commonly reported facilitators to vaccination were external to their organizations. The most commonly reported outer setting facilitators for organizations delivering vaccination were free supplies and local, state, or federal policies or guidelines.
- As with testing, grants, contracts, and awards from federal and state sources were the most commonly reported sources of funding for vaccination efforts across most organization types. Philanthropy and foundation funding was least commonly reported, except by CBOs.

### 1 Challenges implementing vaccination strategies

Exhibit III.7 shows the challenges that survey respondents faced when delivering COVID-19 vaccination services, ordered by how commonly they were reported overall, and organized inner and outer setting domains. Top three most commonly reported challenges for each organization type are shaded (or top four when there was a tie).

Exhibit III.7 Challenges to vaccination strategies, by organization type

Challenge to vaccination strategies | LHDs (n = 39) | FQHCs (n = 30) | CBOs (n = 27) | T/U facilities (n = 17) | Pharmacies (n = 28) | Overall (n = 141)
Inner-setting challenges
Limited staffing | 71.8%^*^ | 60.0%^*^ | 74.1%^*^ | 70.6%^*^ | 75.0%^*^ | 70.2%^*^
Limited time | 35.9% | 26.7% | 37.0% | 23.5% | 67.9%^*^ | 39.0%^*^
Vaccine supplies | 53.8%^*^ | 36.7% | 44.4% | 17.6% | 17.9% | 36.9%
Tracking or following up with people | 38.5% | 30.0% | 29.6% | 35.3%^*^ | 14.3% | 29.8%
Personal protective equipment (PPE) supplies | 35.9% | 40.0% | 29.6% | 5.9% | 21.4% | 29.1%
Data challenges (for example, accessing, collecting, reporting, or tracking data) | 35.9% | 26.7% | 25.9% | 23.5% | 25.0% | 28.4%
Limited expertise | 12.8% | 20.0% | 48.1%^*^ | 11.8% | 7.1% | 19.9%
Ability to refrigerate vaccines | 12.8% | 23.3% | 0.0% | 11.8% | 10.7% | 12.1%
Total inner-setting challenges as a proportion of all challenges | 47.0% | 55.6% | 51.0% | 56.7% | 71.3% | 53.7%
Outer-setting challenges
Misinformation | 76.9%^*^ | 50.0%^*^ | 77.8%^*^ | 41.2%^*^ | 39.3%^*^ | 59.6%^*^
Lack of community trust | 51.3% | 46.7%^*^ | 37.0% | 17.6% | 17.9% | 36.9%
Constraints on use of funding | 48.7% | 16.7% | 37.0% | 29.4% | 3.6% | 28.4%
Managing multiple sources of funding | 51.3% | 26.7% | 18.5% | 17.6% | 3.6% | 26.2%
Limited funding | 20.5% | 30.0% | 40.7% | 5.9% | 14.3% | 23.4%
Low demand from the community for these services | 25.6% | 26.7% | 25.9% | 11.8% | 3.6% | 19.9%
Challenges collaborating or coordinating with partners | 20.5% | 3.3% | 22.2% | 23.5% | 7.1% | 14.9%
Lack of support from local officials | 28.2% | 6.7% | 7.4% | 0.0% | 3.6% | 11.3%
Lack of support from state officials | 12.8% | 3.3% | 11.1% | 5.9% | 3.6% | 7.8%
Total outer-setting challenges as a proportion of all challenges | 53.0% | 44.4% | 49.0% | 43.3% | 28.7% | 46.3%
Other
Other challenges | 5.1% | 0.0% | 0.0% | 11.8% | 10.7% | 5.0%
We did not face any challenges | 2.6% | 3.3% | 0.0% | 11.8% | 0.0% | 2.8%

* Indicates the top three most commonly reported challenges for each organization type (or top four when there was a tie).

Note: Percentages sum to more than 100% because survey respondents were prompted to select all that apply. Ns for each organization type reflect only those that answered each question. Proportions of total inner and outer setting challenges were calculated by tallying challenges for each organization type reported (the denominator), classifying them as either inner-setting or outer-setting (numerators), and calculating a percentage. “Other” challenges are not included in the count of total challenges reported.

CBO = community-based organization; FQHC = Federally Qualified Health Center; T/U = Tribal and Urban Indian Organization; LHD = local health department.

Inner-setting challenges were reported more frequently than outer-setting challenges by all organization types except LHDs. As with testing, the most frequently reported inner-setting challenges were limited staffing (70% overall), and limited time (39%). Limited staffing was reported most by pharmacies (75%) and least by FQHCs (60%). Limited supplies were also a commonly reported challenge for organizations delivering vaccination (37% overall), but less so than for testing (49% overall among testing respondents). Limited expertise and ability to refrigerate vaccines were the least common inner-setting challenges overall (20% and 12%, respectively).

Certain inner-setting challenges differed by organization type, suggesting potential ways to support specific organization types in providing vaccination services. Pharmacies experienced limited time as a challenge at a higher rate than other organizations (68% compared with 39% overall), perhaps related to the challenges they experienced with staffing. CBOs more frequently reported limited expertise as a challenge than other organization types did (48% compared with 20% overall). FQHCs more frequently reported the challenge of being able to refrigerate vaccines than other organization types (23% compared with 12% overall).

Outer-setting challenges were reported less frequently overall but were more prevalent among some organization types. The most prevalent outer-setting challenges were misinformation (60% overall) and lack of community trust (37%). Misinformation was most commonly reported by LHDs (77%) and CBOs (78%), and lack of community trust was reported most by pharmacies (68%). Misinformation and lack of community trust were both more commonly reported among respondents working on vaccination compared to testing, suggesting the populations that respondents worked with were more confident in tests than in vaccines.

Pharmacies did not experience certain outer-setting challenges to the extent other organization types did, especially funding-related challenges. Pharmacies less commonly reported constraints on the use of funding and managing multiple sources of funding than other organization types did (4% compared with 26% to 28% overall). They also less frequently reported challenges with limited funding compared with LHDs, FQHCs, and CBOs (although this was even less common among T/U respondents: 6% compared with 23% overall). Relatively few pharmacies also reported lack of demand for vaccines and lack of federal and local support compared with other organization types.

### 2 Facilitators to implementing vaccination strategies

Exhibit III.8 shows the factors vaccination respondents said helped them promote or deliver vaccination strategies in order of how commonly they were reported overall, within inner- versus outer-setting domains. Top three most commonly reported facilitators for each organization type are shaded (or more when there was a tie).

Exhibit III.8 Facilitators of vaccination strategies, by organization type

Facilitator of vaccination strategies | LHDs (n = 39) | FQHCs (n = 30) | CBOs (n = 26) | T/U facilities (n = 16) | Pharmacies (n = 27) | Overall (n = 138)
Inner-setting facilitators
Careful planning before rollout | 64.1% | 50.0% | 30.8% | 50.0%^*^ | 33.3% | 47.1%
Staff resources | 51.3% | 50.0% | 34.6% | 50.0%^*^ | 40.7%^*^ | 45.7%
Training or education for staff and volunteers | 46.2% | 46.7% | 38.5% | 50.0%^*^ | 33.3% | 42.8%
Volunteer hours or resources | 69.2%^*^ | 20.0% | 34.6% | 12.5% | 18.5% | 35.5%
Use of data to identify trends and disparities | 53.8% | 30.0% | 46.2% | 18.8% | 7.4% | 34.1%
Monitoring or quality improvement | 38.5% | 33.3% | 23.1% | 25.0% | 11.1% | 27.5%
Pilot testing or small-scale test before large-scale rollout | 17.9% | 6.7% | 11.5% | 6.3% | 7.4% | 10.9%
Total inner-setting facilitators as a proportion of all facilitators | 48.0% | 42.3% | 38.0% | 45.3% | 36.3% | 42.9%
Outer-setting facilitators
Free supplies | 84.6%^*^ | 86.7%^*^ | 69.2%^*^ | 87.5%^*^ | 88.9%^*^ | 83.3%^*^
Local, state, or federal policies or guidelines | 69.2%^*^ | 73.3%^*^ | 61.5%^*^ | 56.3%^*^ | 70.4%^*^ | 67.4%^*^
Community or organizational partners | 76.9%^*^ | 53.3%^*^ | 88.5%^*^ | 25.0% | 25.9% | 58.0%^*^
Guidance, information, or best practices from funders, associations, or communities of practice such as learning collaboratives among grantees or program participants | 48.7% | 46.7% | 61.5%^*^ | 50.0%^*^ | 40.7%^*^ | 49.3%
Flexibility in the way funding could be used | 35.9% | 36.7% | 50.0% | 25.0% | 25.9% | 35.5%
Other organizations’ infrastructure, such as physical space or refrigeration | 53.8% | 26.7% | 26.9% | 12.5% | 14.8% | 30.4%
Total outer-setting facilitators as a proportion of all facilitators | 52.0% | 57.7% | 62.0% | 54.7% | 63.7% | 57.1%
Other
Other facilitators | 2.6% | 0.0% | 0.0% | 0.0% | 0.0% | 0.7%

* Indicates the top three most commonly reported facilitators for each organization type (or more when there was a tie).

Note: Percentages sum to more than 100% because survey respondents were prompted to select all that apply. Ns for each organization type reflect only those that answered each question. Proportions of total inner and outer setting facilitators were calculated by tallying facilitators for each organization type reported (the denominator), classifying them as either inner-setting or outer-setting (numerators), and calculating a percentage. “Other” facilitators are not included in the count of total facilitators reported. We classify free supplies as an external facilitator, even though supply shortages are an internal challenge, because specifying “free” relates to the provision of supplies from external parties (including the federal government) and the ability of respondents to obtain those supplies from external parties.

CBO = community-based organization; FQHC = Federally Qualified Health Center; T/U = Tribal and Urban Indian Organization; LHD = local health department.

Outer-setting facilitators were reported more frequently than inner-setting facilitators across all organization types, and they were similar to testing facilitators, potentially reflecting again the need for external support. As with testing, the most common outer-setting facilitator for vaccination overall was free supplies (83%), followed by local, state, or federal policies or guidelines (67%) and community partners (58%). Yet there is some variation across organization types in reporting other facilitators:

- Pharmacies and T/U facilities less commonly reported partners as a facilitator.
- CBOs more commonly reported flexibility in the way funding could be used as a facilitator than other organization types did (50% vs 36% overall).
- Although other organizations’ infrastructure, such as physical space or refrigeration, was the least commonly reported outer-setting facilitator overall (30%), 54% of LHD respondents reported this as a facilitator.

Inner-setting facilitators were less commonly reported overall, and vary by organization type to a larger extent, than outer-setting facilitators. Careful planning before rollout was the most commonly reported inner-setting facilitator overall (47%), followed by staff resources (46%) and training or education for staff and volunteers (43%). CBOs and pharmacies reported these facilitators less often (31% to 41%).

A higher proportion of LHDs reported several inner-setting facilitators than other organization types, potentially reflecting their greater organizational readiness to deliver COVID-19 vaccinations or the similarity of COVID-19 vaccination services to services they provided before the pandemic. These inner-setting facilitators include using data to identify trends and disparities, monitoring quality improvement, pilot testing before large-scale rollout, and especially volunteer hours or resources (69% compared with 36% overall).

### 3 Funding sources for vaccination strategies

Exhibit III.9 shows the proportion of respondents indicating their organization received funding from four different funding sources, plus an “other” category. We organize results by how commonly each funding source was reported overall. Cell shading indicates the most commonly reported funding source for each organization type.

Exhibit III.9 Funding sources for vaccination, by organization type

Funding sources | LHDs (n = 39) | FQHCs (n = 30) | CBOs (n = 26) | T/U facilities (n = 17) | Pharmacies (n = 28) | Overall (n = 140)
Federal funding, such as grants, contracts, or awards | 79.5% | 96.7%^*^ | 73.1%^*^ | 94.1%^*^ | 71.4% | 82.1%^*^
Local or state funding, such as grants, contracts, or awards | 89.7%^*^ | 83.3% | 65.4% | 58.8% | 53.6% | 72.9%
Private insurance or reimbursement | 33.3% | 53.3% | 11.5% | 29.4% | 82.1%^*^ | 42.9%
Philanthropy, foundation, or other nongovernment funding | 0.0% | 20.0% | 61.5% | 5.9% | 7.1% | 17.9%
Other funding source | 2.6% | 0.0% | 0.0% | 0.0% | 0.0% | 0.7%

* Indicates the top three most commonly reported funding sources for each organization type.

Note: Percentages sum to more than 100% because survey respondents were prompted to select all that apply. Ns for each organization type reflect only those that answered each question.

CBO = community-based organization; FQHC = Federally Qualified Health Center; T/U = Tribal and Urban Indian Organization; LHD = local health department.

The most common funding source for COVID-19 vaccinations for each organization type aligns with their typical funding sources, such as local or state funding for LHDs (90%) and private insurance for pharmacies (82%). These findings are similar to those for testing, but an even higher proportion of pharmacies reported use of private insurance for vaccinations than for testing (82% versus 71%).

Respondent insights: Shifts in funding sources and demand for vaccines

As with testing, when asked an open-ended question about how they plan to continue funding their organization’s COVID-19 vaccination efforts, most respondents said they will continue to provide vaccines through federal and state funding, including CDC Bridge Access and Section 317 programs. Also similar to testing, many respondents highlighted that vaccination costs will now shift to insurers and private payers for those who are covered. A few respondents noted that they ceased operation because of low demand for the vaccine, staffing issues, or funding challenges (particularly, the high cost of COVID-19 vaccines).

There are slight but non-substantive differences in the overall proportion of organizations reporting each funding source for vaccination compared with testing. As with testing, federal funding was the most common source of funding for vaccination strategies overall (82%). Funding from local or state sources was also commonly reported overall (73%). Private insurance was less commonly reported overall (43%) other than by pharmacies. Philanthropy, foundation, or other nongovernmental funds was the least commonly reported funding source, reported by 18% of overall respondents and 0% of LHD respondents. The exception was CBOs (62%).

The most common vaccination strategy overall (community-based vaccination clinics) was also most common among organizations reporting all funding sources except for philanthropic funding. For those receiving philanthropic funds, partnering with CBOs was the most common strategy, and respondents tended to be CBOs themselves.