# II Findings on COVID-19 Testing

## A Strategies respondents used to deliver COVID-19 testing

In this section, we describe findings on the strategies respondents reported using to promote or deliver COVID-19 testing. We describe the most prevalent strategies, summarize respondents’ perceptions of which strategies were effective, and describe the partnerships that organizations used to deliver testing strategies.

Key findings

- Many respondents that promoted or provided testing services reported using a large number of strategies to do so, up to 17 out of 18 possible response options, and roughly seven on average. Respondents from FQHCs and LHDs reported the largest number of different strategies, and pharmacies reported the fewest. Because respondents summarized their organizations’ experiences over more than three years, it is not clear from the survey data which strategies they used simultaneously versus sequentially as the pandemic unfolded.
- The most commonly reported strategies were similar across organization types. They included conducting educational outreach using broad tools or media (such as phone calls, text messages, emails, social media, or mass media (TV or radio)), partnering with community organizations and trusted leaders, distributing home tests in community locations, and reducing financial barriers. Open-ended responses confirmed that organizations perceived these strategies as effective.
- Partnerships with government, medical, and community organizations were very common for most organizations delivering COVID-19 testing. Partnerships with businesses, employers or workplaces, and faith-based organizations were less commonly reported overall, but there were key exceptions by organization type. Many respondents reported engaging multiple partners and, in open-ended responses, emphasized the importance of these partnerships, particularly for building trust with communities.
- We did not find evidence that strategies typically fell into certain clusters or combinations.

### 1 COVID-19 testing strategies

Exhibit II.1 shows the number of different strategies^3^ survey respondents reported using to promote or deliver COVID-19 testing to communities at disproportionate risk, by organization type.

Exhibit II.1 Number of different testing strategies used by organizations

Number of different strategies reported | LHDs (n = 38) | FQHCs (n = 31) | CBOs (n = 30) | T/U facilities (n = 20) | Pharmacies (n = 17) | Overall (n = 136)
Min, Max | 2, 17 | 3, 14 | 1, 15 | 2, 16 | 1, 12 | 1, 17
Mean (SD) | 9 (3) | 8 (3) | 7 (4) | 8 (4) | 4 (3) | 8 (4)

CBO = community-based organization; FQHC = Federally Qualified Health Center; T/U = Tribal and Urban Indian Organization; LHD = local health department.

Most organizations reported using multiple testing strategies; the average number was seven (7.47) out of 18 strategies listed as response options. The use of multiple strategies in combination is consistent with guidance from the Community Guide to Preventive Services.^4^ It is not clear from the survey data, however, which strategies organizations used simultaneously versus sequentially over the pandemic period. For example, a respondent selecting three strategies could have used all three in combination throughout their pandemic response effort or one strategy at a time. LHDs and FQHCs reported using the most strategies (averages of nine and eight, respectively). Pharmacies reported using the fewest (average of four), including four out of 17 pharmacies (23%) that reported using only one strategy (four different single strategies, results not shown). This reflects the fact that pharmacies have traditionally offered more specialized services than LHDs and FQHCs, although many pharmacies broadened their COVID-19 offerings in response to the pandemic and changes in their authority brought about by the Public Readiness and Emergency Preparedness Act. Exhibit II.2 shows this information graphically.

Exhibit II.2 Box and whisker plot of minimum, maximum, and median number of different testing strategies reported by respondents of different organization types

Note: Vertical lines in the box and whisker plot (the whiskers) show the range of the number of testing strategies reported by each organization type. If the range includes outliers, such as for pharmacies, they are represented as dots. The horizontal lines within boxes show the median number, and the height of the boxes denotes the middle two quartiles (in which around 50% of the observations fall for each organization type).

CBO = community-based organization; FQHC = Federally Qualified Health Center; T/U = Tribal and Urban Indian Organization; LHD = local health department.

Exhibit II.2 is a box and whisker plot showing the median and range of the number of different testing strategies reported by the surveyed organizations. Local health departments and federally qualified health centers reported the most strategies.

Exhibit II.3 shows the proportion of each organization type that reported using different strategies to deliver or promote COVID-19 testing, in order of how common each strategy was overall. The top five most commonly reported strategies for each organization type are shaded (or top six when there was a tie).

Exhibit II.3 Testing strategies used by organizations that responded to the survey

Strategy | LHDs (n = 38) | FQHCs (n = 31) | CBOs (n = 30) | T/U facilities (n = 20) | Pharmacies (n = 17) | Overall (n = 136)
Conducted educational outreach or campaigns using communication tools or media such as phone calls, text messages, emails, social media, or mass media (TV or radio) | 86.8%^*^ | 83.9%^*^ | 80.0%^*^ | 70.0%^*^ | 41.2%^*^ | 76.5%^*^
Partnered with CBOs such as food banks, churches, or schools or people trusted by community such as religious leaders, school staff, or community health workers | 81.6%^*^ | 77.4%^*^ | 83.3%^*^ | 60.0%^*^ | 23.5% | 70.6%^*^
Distributed home tests in community locations such as at a church, mall, library, community center, school, public housing, or shelter | 81.6%^*^ | 61.3% | 63.3%^*^ | 95.0%^*^ | 41.2%^*^ | 69.9%^*^
Reduced financial barriers such as not requiring health insurance or connecting people with financial resources | 73.7%^*^ | 87.1%^*^ | 33.3% | 55.0%^*^ | 41.2%^*^ | 61.0%^*^
Held community-based testing clinics such as at a church, mall, library, community center, school, public housing, or shelter or events | 71.1%^*^ | 74.2%^*^ | 43.3% | 65.0%^*^ | 29.4%^*^ | 59.6%^*^
Held mass testing clinics sometimes called mega-testing sites, intended to provide a high volume of tests in locations such as stadiums or parking lots or events | 63.2% | 67.7%^*^ | 33.3% | 55.0%^*^ | 29.4%^*^ | 52.2%
Delivered messaging or provided services in multiple languages | 60.5% | 61.3% | 60.0%^*^ | 20.0% | 11.8% | 48.5%
Provided testing services outside of typical business hours or offered walk-in appointments | 63.2% | 64.5% | 16.7% | 50.0% | 35.3%^*^ | 47.8%
Paired testing services with other medical or social services | 39.5% | 54.8% | 43.3% | 45.0% | 23.5% | 42.6%
Held in-person educational events such as a town hall | 28.9% | 29.0% | 56.7%^*^ | 50.0% | 23.5% | 37.5%
Trained partners on how to provide tests or outreach, such as staff in provider organizations | 63.2% | 16.1% | 30.0% | 30.0% | 23.5% | 35.3%
Provided mobile testing services such as with a van | 42.1% | 32.3% | 23.3% | 25.0% | 11.8% | 29.4%
Provided in-home testing services, including mail-in testing programs that allow people to self-test and visited people’s homes to provide testing services there | 36.8% | 25.8% | 23.3% | 35.0% | 11.8% | 27.9%
Eliminated identification requirements to potentially reach people who might be undocumented | 44.7% | 9.7% | 30.0% | 15.0% | 23.5% | 26.5%
Gave out financial incentives such as cash, gift cards, vouchers, or coupons | 13.2% | 12.9% | 36.7% | 35.0% | 0.0% | 19.9%
Gave out non-financial incentives such as food or merchandise | 10.5% | 22.6% | 33.3% | 25.0% | 5.9% | 19.9%
Provided transportation services to testing sites | 13.2% | 19.4% | 10.0% | 45.0% | 0.0% | 16.9%
Other strategy | 5.3% | 3.2% | 10.0% | 0.0% | 5.9% | 5.1%

* Indicates the top five most commonly reported strategies for each organization type (or top six when there was a tie).

Note: Percentages sum to more than 100% because survey respondents were prompted to select all that apply.

CBO = community-based organization; FQHC = Federally Qualified Health Center; T/U = Tribal and Urban Indian Organization; LHD = local health department.

The most commonly reported strategies were largely the same across all organization types, with a few exceptions. The following were the top five overall:

1. Educational outreach via diverse messaging strategies (such as phone calls, social media, text messages, or TV or radio mass media) (77% of all respondents). This was in the top five most common strategies for all organization types and the most common strategy among LHDs (87%) and pharmacies (41%).
2. Partnering with CBOs such as food banks, churches, or schools or people trusted by community such as religious leaders (71% overall). This was the most common strategy reported by CBOs (83%) and in the top five strategies for all organization types except pharmacies.
3. Distributing home tests in community locations (70% overall). This was the most commonly reported strategy among respondents from T/U facilities (95%) and pharmacies (41%) and was among the top five strategies for all organization types except for FQHCs.
4. Reducing financial barriers by not requiring health insurance or connecting people with financial resources^5^ (61% overall). This was most commonly reported among FQHC (87%) and pharmacy (41%) respondents and among the top five strategies for all organization types except CBOs.
5. Community-based testing clinics (60%) was in the top five for all organization types except for CBOs.

Some strategies were more commonly reported by certain organization types. Respondents from LHDs, FQHCs, and CBOs more commonly offered testing services in multiple languages (each about 60% compared with 20% among T/U and 12% among pharmacies). CBOs and T/U respondents more commonly held in-person educational events such as town halls (57% and 50%, respectively, compared with 24% to 29% among the other organization types.) Mass testing was commonly reported by respondents from LHDs (63%), FQHCs (68%), and T/Us (55%), but it was less common for CBO and pharmacy respondents (33% and 29%). Finally, providing transportation to testing sites was uncommon among most organization types (17% overall), except for T/U respondents (45%). In open-ended responses, respondents described other novel strategies such as providing refreshments and creating a welcoming and culturally responsive testing environment.

We did not observe meaningful clusters of testing strategies used in combination, overall or by organization type. To determine whether respondents tended to use certain strategies in combination, we conducted a hierarchical cluster analysis (described in more detail in Section VI). The hierarchical cluster analysis results showed little evidence of an underlying data structure indicating that certain strategies were typically used in combination by different organization types.^6^ This finding suggests that respondents used many varying strategies in combination or they shifted the way they combined strategies over the three years of the pandemic to adapt to changing circumstances. Because the survey did not separately ask about strategies used early or late in the pandemic, or about strategies used when COVID-19 was peaking in certain communities, some respondents might have summarized their organizations’ experiences over a fairly long period to respond to the survey.

### 2 Partnerships for delivering COVID-19 testing

Exhibit II.4 shows the types of organizational partnerships that respondents engaged in to promote or deliver COVID-19 testing, organized by how commonly they were reported overall. (Partnerships were also a survey response option for testing strategies (Exhibit II.3); this exhibit shows responses to a separate question about partnerships that helped respondents carry out any or all of their testing strategies.) The top three most commonly reported partnerships for each organization type are shaded (or top four when there was a tie).

Exhibit II.4 Types of partnerships used to deliver testing services, by organization type

Partner organizations | LHDs (n = 38) | FQHCs (n = 31) | CBOs (n = 26) | T/U facilities (n = 19) | Pharmacies (n = 17) | Overall (n = 131)
Local, state, or federal government offices or programs | 84.2%^*^ | 80.6%^*^ | 73.1%^*^ | 73.7%^*^ | 41.2%^*^ | 74.0%^*^
Community-based organizations | 73.7% | 74.2%^*^ | 84.6%^*^ | 52.6%^*^ | 35.3%^*^ | 67.9%^*^
Medical providers or facilities | 84.2%^*^ | 54.8%^*^ | 88.5%^*^ | 42.1%^*^ | 23.5% | 64.1%^*^
Educational institutions | 76.3%^*^ | 51.6% | 42.3% | 31.6% | 35.3%^*^ | 51.9%
Businesses, employers, or workplaces | 71.1% | 45.2% | 30.8% | 42.1%^*^ | 47.1%^*^ | 49.6%
Faith-based organizations | 50.0% | 48.4% | 65.4% | 15.8% | 17.6% | 43.5%
Other partnership | 0.0% | 0.0% | 0.0% | 0.0% | 5.9% | 0.8%
Did not partner with other organizations | 5.3% | 3.2% | 3.8% | 0.0% | 29.4% | 6.9%

* Indicates the top three most commonly reported partnerships for each organization type (or top four when there was a tie).

Note: Percentages sum to more than 100% because survey respondents were prompted to select all that apply. Ns for each organization type reflect only those that answered each question.

CBO = community-based organization; FQHC = Federally Qualified Health Center; T/U = Tribal and Urban Indian Organization; LHD = local health department.

Partnerships that supported testing were nearly universal among survey respondents. Nearly all (93%) organizations that reported promoting or delivering testing worked in partnership with other organizations (just 7% reported not partnering). LHDs and CBOs reported the greatest variety of partnerships of all organization types (with five different types of partnerships for LHDs and four for CBOs out of a possible six; results not shown). It was also notable that 100% of T/U facilities reported engaging in at least one form of partnership. Respondents elaborated on the effectiveness and importance of partnerships in their open-ended responses about effective strategies (see next section).

A smaller proportion of pharmacies reported engaging in partnerships than the other organization types in the survey. Of the pharmacies that responded to the partnerships question on the survey, 29% reported not partnering with other organizations to promote or deliver testing services. The remaining pharmacy respondents reported partnerships, the most common of which were with businesses, employers, or workplaces (47%).

Exhibit II.5 shows the proportion of respondents that reported engaging in each type of partnership, ordered by how often respondents reported that partnership type overall. The bars represent the proportion of respondents of each organization type that stated they engaged in each form of partnership.

Exhibit II.5 Types of organizations that survey respondents reported partnering with to deliver testing services

CBO = community-based organization; FQHC = Federally Qualified Health Center; T/U = Tribal and Urban Indian Organization; LHD = local health department

Exhibit II.5 is a bar graph showing the types of partners that responding organizations engaged to deliver testing services. Local health departments and federally qualified health centers engaged the most partners.

As shown in Exhibit II.5., more LHDs, FQHCs, and CBOs engaged in most types of partnerships than T/U facilities and pharmacies. One exception to this pattern is that a relatively large proportion of T/U facilities reported partnering with local, state, or federal government offices or programs (74%, similar to other organization types). Another is that a larger proportion of pharmacies partnered with businesses and employers than the proportion of CBOs that did so (47% compared to 31%).

Partnerships with businesses, employers, or workplaces, and faith-based organizations were less commonly reported overall (50% and 44%, respectively), but there were key exceptions. For example, business partnerships were relatively common for LHDs (71%), and partnerships with faith-based organizations were relatively common for CBOs (65%).

### 3 Perceived effectiveness of COVID-19 testing strategies

When asked about the most effective testing strategies used by their organization,^7^ respondents provided free text answers that overwhelmingly focused on strategies to remove barriers to testing and make testing more accessible and convenient, including mass testing and community-based testing events. Drive-through and home testing promoted accessibility and convenience while allowing organizations to “meet people where they are.” Several respondents also mentioned pairing testing with social or medical services, such as testing for people picking up prescriptions or medical supplies or pairing COVID-19 tests with flu shots.

Multiple respondents highlighted the importance of partnerships, noting the importance of identifying local trusted partners and messengers that helped the organization build trust and relationships with community members. A common theme from respondents was that building trust and rapport was key to testing uptake.

A few respondents mentioned additional strategies that they saw as effective. These included providing child care to increase convenience, calling everyone in a community to provide testing information, leveraging community health workers or lay health advisors to provide education and information, distributing tests at gas stations, and using a local radio station to provide updates to remote communities.

Finally, some respondents noted the effectiveness or importance of focusing on specific populations or community members through events and messaging. These included populations identified by respondents as minority groups, underserved groups, working class and low-income people, and unhoused people. Respondents described the importance of using multilingual approaches, culturally relevant or culturally adapted materials and communication, and appropriate literacy levels. Some respondents also noted that word of mouth was a quick way to spread messaging and education.

## B Populations of focus for COVID-19 testing strategies

In this section, we describe findings about the populations of focus for respondents’ testing efforts. We also describe patterns in the strategies respondents used to promote or provide testing to these populations.

Key findings

- LHDs and FQHCs reported the broadest range of populations of focus, whereas pharmacies and T/U facilities reported the fewest.
- Respondents from all organization types focused on serving older adults, while incarcerated persons were the least commonly reported population of focus.
- Some organization types more commonly provided testing to specific populations. For example, LHDs focused on people with underlying medical conditions, CBOs and FQHCs focused on people facing economic insecurity, T/U facilities focused on serving American Indian and Alaska Native populations, and pharmacies focused on testing frontline workers.
- Most organizations reported similar strategies regardless of their primary populations of focus; these strategies tended to be broad and adaptable to the needs of different populations, like promoting services via multiple communication streams and engaging trusted community leaders. Some organizations serving specific populations reported strategies that may have helped people overcome barriers, for example related to English language or transportation.

### 1 Populations of focus for testing strategies

Exhibit II.6 shows the populations of focus^8^ among respondents that worked on testing, in order of how commonly each population was reported overall. We shade table cells in which at least 75% of respondents of each organization type reported a population of focus (this is a data-driven cutoff that we chose to aid analysis and comprehension). The table also summarizes the total number of different populations of focus that each organization type reported. Note that we cannot determine whether organizations focused on all populations simultaneously or at different points in the pandemic. Table cells in which at least 75% of respondents of each organization type reported a population of focus are shaded.

Exhibit II.6 Populations of focus, by organization type

Population | LHDs (n = 37) | FQHCs (n = 31) | CBOs (n = 26) | T/U facilities (n = 19) | Pharmacies (n = 17) | Overall (n = 130)
Older adults (older than age 65) | 97.3%^*^ | 96.8%^*^ | 92.3%^*^ | 100.0%^*^ | 100.0%^*^ | 96.9%^*^
Young adults (ages 18 to 24) | 83.8%^*^ | 87.1%^*^ | 92.3%^*^ | 94.7%^*^ | 64.7% | 85.4%^*^
People without health insurance | 75.7%^*^ | 96.8%^*^ | 76.9%^*^ | 63.2% | 64.7% | 77.7%^*^
People or communities with low income | 70.3% | 90.3%^*^ | 88.5%^*^ | 63.2% | 64.7% | 76.9%^*^
People with specific underlying medical conditions | 94.6%^*^ | 87.1%^*^ | 50.0% | 63.2% | 70.6% | 76.2%^*^
Frontline workers or other people at increased risk of COVID-19 because of their occupation such as migratory and seasonal agricultural workers | 81.1%^*^ | 80.6%^*^ | 53.8% | 78.9%^*^ | 82.4%^*^ | 75.4%^*^
Children (ages 0 to 17) | 86.5%^*^ | 74.2% | 53.8% | 89.5%^*^ | 47.1% | 72.3%
Communities in a specific geographic area (for example, neighborhoods, wards, or towns, or areas defined by high need) | 64.9% | 71.0% | 73.1% | 84.2%^*^ | 41.2% | 67.7%
Hispanic communities | 81.1%^*^ | 80.6%^*^ | 80.8%^*^ | 5.3% | 41.2% | 64.6%
People with disabilities (for example, physical disabilities, intellectual disabilities, visual impairments) | 67.6% | 71.0% | 42.3% | 84.2%^*^ | 52.9% | 63.8%
Rural communities | 70.3% | 54.8% | 61.5% | 68.4% | 52.9% | 62.3%
People or communities with low education or literacy | 54.1% | 87.1%^*^ | 73.1% | 31.6% | 47.1% | 61.5%
People with limited English proficiency | 70.3% | 80.6%^*^ | 69.2% | 15.8% | 35.3% | 60.0%
Black or African American communities | 64.9% | 67.7% | 73.1% | 10.5% | 47.1% | 56.9%
People with substance use disorder | 43.2% | 71.0% | 34.6% | 52.6% | 41.2% | 49.2%
American Indian or Alaska Native communities | 45.9% | 45.2% | 38.5% | 94.7%^*^ | 29.4% | 49.2%
Immigrant communities, including refugees and people without documentation | 59.5% | 64.5% | 53.8% | 5.3% | 29.4% | 47.7%
People in multigenerational housing | 29.7% | 64.5% | 57.7% | 52.6% | 23.5% | 46.2%
Residents of public housing | 43.2% | 54.8% | 57.7% | 26.3% | 29.4% | 44.6%
People experiencing homelessness or housing insecurity | 45.9% | 54.8% | 50.0% | 26.3% | 17.6% | 42.3%
Lesbian, gay, bisexual, transgender, queer/questioning, intersex, asexual/agender, and two-spirit (LGBTQIA2S+) populations | 32.4% | 67.7% | 34.6% | 26.3% | 29.4% | 40.0%
Asian communities | 54.1% | 48.4% | 34.6% | 0.0% | 29.4% | 37.7%
Residents of shelters | 51.4% | 41.9% | 34.6% | 10.5% | 17.6% | 35.4%
Veterans | 32.4% | 45.2% | 23.1% | 31.6% | 41.2% | 34.6%
Residents of nursing homes or long-term care facilities | 59.5% | 22.6% | 11.5% | 10.5% | 41.2% | 31.5%
Native Hawaiian or other Pacific Islander communities | 40.5% | 35.5% | 26.9% | 5.3% | 23.5% | 29.2%
Incarcerated populations | 48.6% | 6.5% | 3.8% | 5.3% | 0.0% | 16.9%
Other populations or communities of focus | 2.7% | 0.0% | 3.8% | 0.0% | 0.0% | 1.5%
Number of different populations of focus reported
Min, Max | 6, 27 | 3, 27 | 5, 25 | 3, 24 | 1, 26 | 1, 27
Mean (SD) | 16.5 (6.4) | 17.5 (5.9) | 14.5 (6.1) | 12.0 (4.8) | 11.7 (8.3) | 15.04 (6.6)

* Indicates table cells in which at least 75% of respondents of each organization type reported a population of focus.

Note: Percentages sum to more than 100% because survey respondents were prompted to select all that apply. Ns for each organization type reflect only those that answered each question.

CBO = community-based organization; FQHC = Federally Qualified Health Center; T/U = Tribal and Urban Indian Organization; LHD = local health department.

Nearly all organizations that responded to this survey question reported focusing on older adults; most also focused on young adults, and relatively few focused on incarcerated persons. Older adults were the most commonly reported population of focus overall (97%) and among all organization types. At least 75% of respondents across all organization types reported focusing on younger adults ages 18 to 24, with the exception of pharmacies. Incarcerated persons were the least commonly reported population of focus overall (17%), though 49% of LHD respondents offered testing services to this population.

Aside from older and young adults, populations of focus reported by at least 75% of respondents differed by organization type and largely aligned with each organization type’s typical mission. We present these results in order of the number of different populations of focus each organization type reported.

- FQHCs reported the greatest number and variety of populations of focus (18 on average). In addition to focusing on a relatively large number of different patient groups, FQHCs reported focusing on several groups that could be characterized as facing economic insecurity, including people without health insurance, people with low income, people with low education, and people with limited English proficiency. FQHCs also more commonly reported serving LGBTQI2S+ populations compared with other organization types (68% compared with 45% overall).
- LHDs also reported many populations of focus, similar to FQHCs (17 on average). Similar to FQHCs, LHDs commonly served people with underlying medical conditions, frontline workers, people without health insurance, and Hispanic communities. LHDs were distinguished from FQHCs by their greater focus on children (87% versus 74%), residents of nursing homes (60% versus 23%), and incarcerated populations (48% versus 7%).
- Similar to FQHCs and LHDs, CBOs tended to focus on people facing economic insecurity. CBOs reported 14 populations of focus on average, but only five were reported by at least 75% of respondents; they included people without health insurance or low income.
- T/U facilities were unique in some of their populations of focus. T/U facilities reported 12 populations of focus on average. Compared with other organization types, T/U facilities overwhelmingly focused on American Indian and Alaska Native populations (95% versus 49% overall) and communities in a defined geographic region (84% versus 67% overall), which is unsurprising because of these organizations’ mission and reach. American Indian and Alaska Native respondents also more commonly focused on children and people with disabilities than other organization types did. Similar to FQHCs and LHDs, T/U also respondents focused on frontline workers.
- Pharmacies reported the fewest populations of focus. Similar to T/U respondents, pharmacies reported 12 populations of focus on average, but only two were reported by at least 75% of respondents: older adults and frontline workers. It is possible that this finding reflects that many pharmacies simply serve as many customers or community members as they can without distinguishing specific groups.

### 2 Patterns of strategies used and populations of focus

Here, we describe the most commonly reported testing strategies among organizations that reported focusing on each specific population (our analytic approach is described in Section VI). For example, among the 126 respondents serving older adults, 76% also reported conducting educational outreach campaigns. These results do not reveal whether an organization used a given approach to serve a specific population. For example, the above finding does not necessarily mean that the educational outreach campaigns were offered to or accessed by older adults, but it does reveal that organizations serving older adults commonly also provided educational outreach. We do not include the exhibit of results because of its large size.

The most common strategies were the same among respondents focusing on many diverse populations. For example, conducting educational outreach or campaigns using diverse media and communication tools was the most commonly reported strategy overall and among respondents focusing on children, young adults, older adults, Hispanic communities, Black communities, LGBTQI2S+ populations, and many others. Partnering with CBOs and trusted community members was the second most commonly reported strategy overall and the most common among respondents serving immigrants, people with limited English proficiency, people in multigenerational housing, and others. Other common strategies, such as distributing tests in community locations and reducing financial barriers, were the most commonly reported strategies among organizations focusing on the remaining populations, such as people with disabilities, people with substance use disorder, and certain racial and ethnic groups.

Top strategies such as conducting educational outreach and partnering with other organizations may have been tailored to meet the needs of diverse populations. The top strategies used by respondents serving diverse populations were broadly worded to encompass multiple variations, such as communication through phone calls or mass media, engaging different kinds of trusted leaders, and distributing testing in various community locations. The encompassing nature of the response option wording—and the inherent adaptability of these strategies—likely explains why they were so commonly reported, and suggests they might have helped organizations reach diverse populations with different needs, resources, risk factors, and circumstances.

Some strategies, although less commonly reported overall, were substantially (greater than 10%) more commonly reported among respondents focusing on particular populations; they tended to be strategies to overcome barriers. For example, delivering testing or providing services in multiple languages was more commonly reported by organizations that focused on Hispanic communities (66%); people with limited English proficiency (67%); and immigrants, refugees, and people without documentation (69% compared with 48% overall; results not shown). Providing in-home testing was reported by 42% of respondents who focused on residents of nursing homes and 41% of respondents who focused on residents of public housing (compared with 28% of overall respondents to this question).

We did not observe meaningful archetypes or organizations of certain types that tended to use certain testing strategies for specific populations of focus. We used cluster analysis to assess whether organization type, testing strategy, and population of focus clustered together in any meaningful patterns. As with the simple cluster analysis of strategies (described in Section II.B.1), we did not identify archetypes. Although organizations that responded to the survey used many different strategies, and served many populations, there was no meaningful pattern of combinations of strategies used for specific populations by certain organization types.

## C Barriers to, facilitators of, and funding for COVID-19 testing strategies

Here, we describe findings on the factors that made testing strategies more difficult or easier for respondents to deliver. Following the Consolidated Framework for Implementation Research (CFIR, Damschroder et al. 2022), one of the theoretical frameworks guiding our analysis for the overall study, we categorize implementation challenges as operating in inner or outer settings. The CFIR is useful for understanding whether challenges and facilitators fall within the responding organization (referred to as the “inner-setting”) or in their external context (referred to as the “outer setting). This information can help funders, partners, and policymakers provide the most useful supports to organizations. We also discuss findings on funding for testing strategies.

Key findings

- Respondents across organization types reported challenges to delivering COVID-19 testing, both internal and external to the organizations. Inner setting challenges were slightly more common, and included things like staffing and supply shortages. Our finding that staffing was the most common challenge overall, by a substantial margin, is consistent with widely reported shortages in the health care and public health workforces during and after the pandemic. Outer setting challenges were slightly less common, except for misinformation, which was among the top challenges reported by most respondents.
- In contrast, organizations more commonly reported facilitators of COVID-19 testing that were external to their organizations. Taken together with the finding that challenges with the inner setting were more common than with the outer setting, this reflects that many organizations were not well set up internally to deliver testing services, at least right away, and therefore needed supports from outside.
- Most organizations that reported working on testing were funded through multiple sources; and federal funding was the most commonly reported source overall. Within organization types, the most commonly reported source aligned with typical funding sources, such as local or state funding for LHDs and private insurance for pharmacies. Common testing strategies were largely the same regardless of funding source.

### 1 Challenges to implementing testing strategies

Exhibit II.7 shows the distribution of challenges faced by organizations working on testing, in order of how commonly each challenge was reported overall within inner- versus outer-setting domains of the Consolidated Framework for Implementation Research (CFIR, Damschroder et al. 2022). Nearly all respondents that worked on testing reported facing at least some challenges (96%). Inner-setting challenges are internal to an organization, such as those related to staffing, time, supplies, and infrastructure. Outer-setting challenges occur in the context surrounding an organization, such as those related to funding, local connections, community attitudes, and external pressures. This framework is useful because it suggests the need for different types of solutions to help organizations improve their effectiveness. The table also presents the total number of challenges (mean, SD, and range) reported by each organization type. Top three most commonly reported challenges for each organization type are shaded (or top four when there was a tie).

Over half of all reported challenges were internal to the organizations delivering testing (55%). The most prevalent inner-setting challenges overall were limited staffing (69%), testing supplies (49%), and limited time (41%). Our finding that staffing was the largest challenge across the board is consistent with well known and widely reported health care and public health staffing shortages during and after the pandemic; it is striking that CBOs reported the same thing.^9^ The organization types reporting the highest proportion of challenges in the inner setting were pharmacies and FQHCs, with 62% and 59% of all challenges characterized as inner setting challenges (results not shown).

Exhibit II.7 Challenges to testing strategies, by organization type

Challenge to testing strategies | LHDs (n = 37) | FQHCs (n = 31) | CBOs (n = 26) | T/U facilities (n = 19) | Pharmacies (n = 17) | Overall (n = 130)
Inner-setting challenges
Limited staffing | 78.4%^*^ | 58.1%^*^ | 69.2%^*^ | 78.9%^*^ | 58.8%^*^ | 69.2%^*^
Testing supplies | 48.6%^*^ | 48.4%^*^ | 61.5%^*^ | 31.6% | 47.1%^*^ | 48.5%^*^
Limited time | 45.9% | 29.0% | 38.5% | 36.8%^*^ | 58.8%^*^ | 40.8%
Personal protective equipment (PPE) supplies | 40.5% | 54.8% | 30.8% | 15.8% | 23.5% | 36.2%
Tracking or following up with people | 37.8% | 48.4% | 34.6% | 31.6% | 5.9% | 34.6%
Data challenges (for example, accessing, collecting, reporting, or tracking data) | 32.4% | 29.0% | 23.1% | 5.3% | 17.6% | 23.8%
Limited expertise | 18.9% | 22.6% | 34.6% | 15.8% | 5.9% | 20.8%
Total inner-setting challenges as a proportion of all challenges | 52.3% | 59.2% | 53.5% | 52.6% | 63.8% | 55.3%
Outer-setting challenges
Misinformation | 59.5%^*^ | 48.4%^*^ | 61.5%^*^ | 31.6% | 29.4% | 49.2%^*^
Limited funding | 29.7% | 25.8% | 61.5%^*^ | 15.8% | 41.2% | 34.6%
Lack of community trust | 40.5% | 38.7% | 34.6% | 10.5% | 0.0% | 29.2%
Constraints on use of funding | 32.4% | 22.6% | 34.6% | 42.1%^*^ | 11.8% | 29.2%
Managing multiple sources of funding | 40.5% | 22.6% | 19.2% | 36.8% | 5.9% | 26.9%
Challenges collaborating or coordinating with partners | 21.6% | 12.9% | 15.4% | 31.6% | 11.8% | 18.5%
Low demand from the community for these services | 21.6% | 19.4% | 19.2% | 21.1% | 0.0% | 17.7%
Lack of support from local officials | 21.6% | 6.5% | 3.8% | 0.0% | 11.8% | 10.0%
Lack of support from state officials | 8.1% | 3.2% | 3.8% | 5.3% | 11.8% | 6.2%
Total outer-setting challenges as a proportion of all challenges | 47.7% | 40.8% | 46.5% | 47.4% | 36.2% | 44.7%
Other
Other challenges | 2.7% | 0.0% | 0.0% | 0.0% | 5.9% | 1.5%
Did not face any challenges | 2.7% | 0.0% | 3.8% | 10.5% | 5.9% | 3.8%

* Indicates the top three most commonly reported challenges for each organization type (or top four when there was a tie).

Note: Percentages sum to more than 100% because survey respondents were prompted to select all that apply. Ns for each organization type reflect only those that answered each question. Proportions of total inner and outer setting challenges were calculated by tallying challenges for each organization type reported (the denominator), classifying them as either inner-setting or outer-setting (numerators), and calculating a percentage. “Other” challenges are not included in the count of total challenges reported.

CBO = community-based organization; FQHC = Federally Qualified Health Center; T/U = Tribal and Urban Indian Organization; LHD = local health department.

Challenges with tracking or following up with people and limited expertise stood out as relatively rare inner-setting challenges for pharmacies. Only 5.9% of pharmacies reported difficulty following up with people, although it is not clear whether pharmacies did less of this overall or simply did not experience challenges doing it. The same proportion of pharmacies (5.9%) reported limited staff expertise, which could reflect the fact that staff provided a narrower scope of services more in line with their training, compared to staff in other organizations who may have been required to do new things to meet new demands. It was also notable that only 5.3% of T/U facilities reported challenges with data.

Outer-setting challenges were less commonly reported overall but were more common among some organization types. The most commonly reported outer-setting challenges were misinformation (49% overall and up to roughly 60% among CBOs and LHDs) and limited funding (35% overall but 62% among CBOs and 60% among LHDs). Other outer-setting challenges included constraints on use of funding, which was more commonly reported among T/U facilities (41%) compared with other organization types (29% overall) and lack of community trust, which was higher among LHD and FQHC respondents (41% and 35%) than among respondents from other organization types such as T/Us (only 11% of which reported this challenge). No pharmacy respondents reported challenges related to community trust or demand for their services. Four of the five least commonly reported challenges were related to the outer setting, including coordinating with partners, low demand for services, and lack of support from local or state officials (all less than 20% overall). In open-ended responses, respondents additional challenges such as the community’s frustration with vaccine eligibility.

### 2 Facilitators to implementing testing strategies

Exhibit II.8 shows the factors that respondents said helped them promote or deliver testing strategies in order of how commonly each facilitator was reported overall. The table is organized by inner- versus outer-setting domains of the Consolidated Framework for Implementation Research (CFIR, Damschroder et al. 2022). Top three most commonly reported facilitators for each organization type are shaded (or more when there was a tie).

Exhibit II.8 Facilitators of testing strategies, by organization type

Facilitator of testing strategies | LHDs (n = 38) | FQHCs (n = 31) | CBOs (n = 26) | T/U facilities (n = 19) | Pharmacies (n = 17) | Overall (n = 131)
Inner-setting facilitators
Staff resources | 47.4% | 48.4% | 50.0% | 52.6%^*^ | 41.2%^*^ | 48.1%
Training or education for staff and volunteers | 52.6% | 51.6%^*^ | 53.8% | 36.8% | 35.3% | 48.1%
Careful planning before rollout | 50.0% | 48.4% | 26.9% | 47.4% | 29.4% | 42.0%
Use of data to identify trends and disparities | 55.3% | 32.3% | 53.8% | 31.6% | 0.0% | 38.9%
Monitoring or quality improvement | 47.4% | 48.4% | 19.2% | 26.3% | 11.8% | 34.4%
Volunteer hours or resources | 57.9% | 16.1% | 42.3% | 5.3% | 11.8% | 31.3%
Total inner-setting facilitators as a proportion of all facilitators | 45.9% | 42.7% | 43.2% | 40.9% | 46.8% | 44.0%
Outer-setting facilitators
Free supplies | 97.4%^*^ | 87.1%^*^ | 69.2%^*^ | 94.7%^*^ | 52.9%^*^ | 83.2%^*^
Local, state, or federal policies or guidelines | 73.7%^*^ | 74.2%^*^ | 42.3% | 63.2%^*^ | 64.7%^*^ | 64.9%^*^
Community or organizational partners | 73.7%^*^ | 51.6%^*^ | 84.6%^*^ | 47.4% | 11.8% | 58.8%^*^
Flexibility in the way funding could be used | 50.0% | 51.6%^*^ | 42.3% | 36.8% | 11.8% | 42.0%
Guidance, information, or best practices from funders, associations, or communities of practice such as learning collaboratives among grantees or program participants | 36.8% | 45.2% | 61.5%^*^ | 36.8% | 5.9% | 39.7%
Other organizations’ infrastructure, such as physical space or refrigeration | 34.2% | 19.4% | 23.1% | 10.5% | 0.0% | 20.6%
Total outer-setting facilitators as a proportion of all facilitators | 54.1% | 57.3% | 56.8% | 59.1% | 53.2% | 56.0%
Other
Other facilitators | 2.6% | 6.5% | 0.0% | 0.0% | 0.0% | 2.3%

* Indicates the top three most commonly reported facilitators for each organization type (or more when there was a tie).

Note: Percentages sum to more than 100% because survey respondents were prompted to select all that apply. Ns for each organization type reflect only those that answered each question. Proportions of total inner and outer setting facilitators were calculated by tallying facilitators for each organization type reported (the denominator), classifying them as either inner-setting or outer-setting (numerators), and calculating a percentage. “Other” facilitators are not included in the count of total facilitators reported. We classify free supplies as an external facilitator, even though supply shortages are an internal challenge, because specifying “free” relates to the provision of supplies from external parties (including the federal government) and the ability of respondents to obtain those supplies from external parties.

CBO = community-based organization; FQHC = Federally Qualified Health Center; T/U = Tribal and Urban Indian Organization; LHD = local health department.

More than half of all facilitators were external to the organizations working on testing, potentially reflecting that many organizations were engaging in new and demanding work during the pandemic and needed external support. Because of the disruptive nature of the pandemic, many organizations might not have been well set up internally to deliver testing services, at least right away. The three most commonly reported facilitators overall and for most organization types were free supplies (83%); local, state, or federal policies or guidelines (65%); and community or organizational partners (59%). Pharmacies were an exception to this pattern; they did not commonly report community or organizational partnerships as a facilitator (12% compared with 59% overall). Outer-setting facilitators were most commonly reported among respondents from FQHCs, CBOs, and T/Us.

Inner-setting facilitators were slightly less common but still prevalent. Just under half of all facilitators identified among respondents that delivered testing were internal to organizations. The most commonly reported inner-setting facilitators included staff resources (48%), training or education for staff and volunteers (48%), and careful planning before rollout (42%).

### 3 Funding sources for testing strategies

Exhibit II.9 shows the proportion of respondents indicating their organization received funding from each of four funding sources in order of how commonly each funding source was reported overall. Cell shading indicates the most commonly reported funding source for each organization type.

Exhibit II.9 Funding sources for testing, by organization type

Funding sources | LHDs (n = 37) | FQHCs (n = 31) | CBOs (n = 24) | T/U facilities (n = 19) | Pharmacies (n = 17) | Overall (n = 128)
Federal funding, such as grants, contracts, or awards | 75.7% | 93.5%^*^ | 66.7%^*^ | 100.0%^*^ | 35.3% | 76.6%^*^
Local or state funding, such as grants, contracts, or awards | 89.2%^*^ | 74.2% | 62.5% | 52.6% | 23.5% | 66.4%
Private insurance or reimbursement | 27.0% | 45.2% | 16.7% | 15.8% | 70.6%^*^ | 33.6%
Philanthropy, foundation, or other nongovernment funding | 0.0% | 22.6% | 58.3% | 10.5% | 17.6% | 20.3%
Other funding source | 0.0% | 0.0% | 0.0% | 0.0% | 5.9% | 0.8%

* Indicates the most commonly reported funding source for each organization type.

Note: Percentages sum to more than 100% because survey respondents were prompted to select all that apply. Ns for each organization type reflect only those that answered each question. The item response rate for this question was lower for CBO respondents than for other organization types (80% versus 94% overall).

CBO = community-based organization; FQHC = Federally Qualified Health Center; T/U = Tribal and Urban Indian Organization; LHD = local health department.

The most common funding source for testing for each organization type aligns with their typical funding sources, such as local or state funding for LHDs (89%) and private insurance for pharmacies (71%). CBOs reported the most even distribution of funding sources, across federal (67%), local and state (63%), and philanthropic funding (58%), and other organization types reported using one source substantially more than others.

Respondent insights: Plans for continued funding

When asked how they plan to continue funding their organization’s COVID-19 testing efforts, multiple respondents that provided free-text answers said they will continue to provide testing through federal, state, and grant funding, including funding for Indian Health Service facilities and FQHCs. Many of these respondents noted that they will receive tests rather than funding directly from these sources. Some respondents noted shifting from a public health approach to normal health care system operations by shifting testing costs to insurance or self-pay. A few respondents noted they are no longer providing testing services or will stop soon, with one explaining that they are instead focused on education and others citing high costs or no available funding at all.

Federal funding was the most common source of funding for testing overall (77%). Funding from local or state sources was also commonly reported overall (66%). Private insurance was less commonly reported overall (34%) with the exception of pharmacies (71%). Philanthropy, foundation, or other nongovernmental funds was the least commonly reported funding source (20% overall and 0% among LHDs). The exception was CBOs (58%).

Common testing strategies were the same regardless of funding source, with a few exceptions. For example, organizations funded by all sources typically conducted educational outreach or campaigns using diverse tools or media or partnered with CBOs (results not shown). There were a few exceptions in which certain strategies were more common among organizations receiving specific funding streams: those receiving private insurance more commonly reported operating community-based clinics, and those receiving local and federal funding more commonly distributed home tests in community locations. Finally, those receiving philanthropic funding most commonly reported delivering testing services in multiple languages. These findings might be driven by organization type (for example, CBOs were more commonly funded by philanthropies and also more commonly offered services in multiple languages than other organization types).

3 We use the word strategies for all activities related to testing (and vaccination) for consistency with the word used in the survey instrument. Note, however, that we characterized some strategies as approaches in the environmental scan report because they referred to the primary mechanisms that organizations use to achieve intended COVID-19 vaccination and testing access, awareness, and confidence. They include educational campaigns and in-person educational events, mobile testing/vaccination, community-based testing/vaccination, and mass-testing/vaccination. Strategies, in contrast, describe the activities designed to make primary approaches effective and further engage their effectiveness by focusing on the needs of participants, such as expanding hours or providing translation services.

4 See Vaccination Programs: Health Care System-Based Interventions Implemented in Combination | The Community Guide (https://www.thecommunityguide.org/findings/vaccination-programs-health-care-system-based-interventions-implemented-combination.html).

5 In open-ended responses, respondents described reducing financial barriers by offering testing free of charge or by not requiring insurance to be tested. Respondents did not elaborate on connecting people to financial resources, however roughly 20% of respondents reported giving out financial incentives.

6 The average silhouette width for all possible clusters (ranging from 1 to 20) among each organization type was less than 0.5, indicating that “the structure is weak and could be artificial” (see Rouseeuw 1987).

7 The survey question was: “From the strategies you previously selected, please choose the most effective COVID-19 testing strategies your organization used to increase testing awareness, access, or uptake for populations who are medically or socially at disproportionate risk for COVID-19 or adverse outcomes.” A follow-up question asked: “Please describe how the COVID-19 testing strategies you selected were effective.”

8 The survey question was: “Who were the populations or communities of focus for your organization’s COVID-19 testing strategies during the COVID-19 public health emergency?” A parallel question was asked of respondents who worked on vaccination.

9 See, for example, findings from larger surveys on decreases on the public health workforce during the pandemic: The Exodus Of State And Local Public Health Employees: Separations Started Before And Continued Throughout COVID-19 | Health Affairs (https://www.healthaffairs.org/doi/10.1377/hlthaff.2022.01251), and on pharmacy staffing shortages: Three-quarters of pharmacists say lack of staff is hindering their job performance - The Pharmaceutical Journal (pharmaceutical-journal.com) (https://pharmaceutical-journal.com/article/news/three-quarters-of-pharmacists-say-lack-of-staff-is-hindering-their-job-performance).