# I Introduction

This report presents findings from the National Survey on Best Practices for COVID-19 Vaccination and Testing, part of the Best Practices for COVID-19 Testing and Vaccination Study sponsored by the Office of the Assistant Secretary for Planning and Evaluation (ASPE) and the Office of the Assistant Secretary for Health (OASH). The survey was designed to gather information from local organizations about their efforts to improve COVID-19 testing and vaccination in populations that are medically or socially at disproportionate risk for COVID-19 or related adverse outcomes.^1^ Findings from this analysis of survey data are primarily descriptive and serve to broaden our understanding of the testing and vaccination strategies that local organizations used most frequently, their populations of focus, the challenges they experienced in helping those populations, and other attributes of their efforts that address our research questions and inform subsequent study phases.. Following the completion of the survey, the research team conducted virtual site visits with public health leaders, program staff and partners, and community members participating in COVID-19 vaccination and testing programs in 7 US states and 2 tribal organizations. The findings described in this report were used to provide context for qualitative data gathered through these site visits.

Overview of initial survey sample. As described in the survey plan (finalized and submitted to ASPE on May 18, 2023), we administered the survey to representatives of five organization types: local health departments (LHDs); Federally Qualified Health Centers (FQHCs); community-based organizations (CBOs); community pharmacies (herein, pharmacies); and Indian Health Service, tribal, and Urban Indian Organization health facilities (collectively, I/T/U facilities). We administered the survey over a 10-week fielding period from September 19, 2023, to November 27, 2023. We invited 507 representatives from the organizations to complete the survey. See Section VI for additional details on the sample and survey administration.

Overview of respondents. We received 164 completed surveys, with an overall response rate of 35%. Exhibit I.1 shows the number of respondents for each organization type and how they compared to the initial sample. Response rates are similar for most organization types but notably lower for Indian Health Services and tribal facilities. Because we did not receive any responses from Indian Health Service facilities, the following analysis refers to tribal and Urban Indian Organization (T/U) facilities only.

Exhibit I.1 Response rates by organization type

Survey status | LHDs (n = 101) | FQHCs (n = 100) | CBOs (n = 103) | I/T/U facilities (n = 100) | | | Pharmacies (n = 103) | Total (n = 507)
Survey status | LHDs (n = 101) | FQHCs (n = 100) | CBOs (n = 103) | IHS | Tribal | UIO | Pharmacies (n = 103) | Total (n = 507)
Eligible survey completes | 40 | 31 | 39 | 0 | 19 | 4 | 31 | 164
Ineligible | 4 | 3 | 9 | 1 | 6 | 0 | 9 | 32
Refusal | 0 | 0 | 4 | 0 | 1 | 0 | 3 | 8
Incomplete | 57 | 66 | 51 | 10 | 53 | 6 | 60 | 302
Total invitations | 101 | 100 | 103 | 11 | 79 | 10 | 103 | 507
Eligible sample | 97 | 97 | 94 | 10 | 73 | 10 | 94 | 475
Response rate | 41% | 32% | 41% | 0% | 26% | 40% | 33% | 35%

Note: Ineligibles included organizations that are no longer in operation, are a duplicate of another organization in the sample, or did not provide COVID-19 testing, vaccinations, or information about testing or vaccination. Most ineligible respondents are a duplicate of another already in the sample or are no longer in operation.

CBO = community-based organization; FQHC = Federally Qualified Health Center; IHS = Indian Health Services; I/T/U = Indian Health Service, tribal, and Urban Indian Organization; LHD = local health department; UIO = Urban Indian Organization.

The survey asked separate sets of questions about testing and vaccination activities (see the survey instrument in the Appendix). Therefore, we present most findings separately for organizations that worked on testing (alone or in combination with vaccination; n = 136) and vaccination (alone or in combination with testing, n = 146). Out of 164 total respondents to the survey, 118 delivered testing and vaccination services, 18 delivered testing only, and 28 delivered vaccination only, totaling 136 organizations delivering testing and 146 delivering vaccination. Of the organizations that reported testing or vaccination services, LHDs comprised the largest proportion of the respondents overall (38 and 39 respondents, respectively). The next most common organization types reporting either testing or vaccination services were FQHCs and CBOs, followed by T/U facilities and community pharmacies. Exhibit I.2 shows the distribution of organizations that provided testing versus vaccination by organization type and by state. Exhibit I.3 shows the percentage of each organization type that worked on testing versus vaccination.

Exhibit I.2 Characteristics of organizations that provided testing versus vaccination (N = 164)

Organization type | Testing | Vaccination
LHDs | 38 (27.9%) | 39 (26.7%)
FQHCs | 31 (22.8%) | 30 (20.5%)
CBOs | 30 (22.1%) | 30 (20.5%)
T/U facilities | 20 (14.7%) | 18 (12.3%)
Community pharmacies | 17 (12.5%) | 29 (19.9%)
All organization types | 136 (100%) | 146 (100%)
State
AK | 5 (3.7%) | 7 (4.8%)
AL | 6 (4.4%) | 8 (5.5%)
AZ | 8 (5.9%) | 8 (5.5%)
CA | 7 (5.1%) | 9 (6.2%)
FL | 2 (1.5%) | 2 (1.4%)
IL | 7 (5.1%) | 6 (4.1%)
IN | 6 (4.4%) | 6 (4.1%)
KS | 7 (5.1%) | 6 (4.1%)
MA | 7 (5.1%) | 8 (5.5%)
MI | 8 (5.9%) | 8 (5.5%)
MO | 9 (6.6%) | 9 (6.2%)
MS | 4 (2.9%) | 4 (2.7%)
NC | 10 (7.4%) | 9 (6.2%)
NJ | 5 (3.7%) | 5 (3.4%)
NM | 5 (3.7%) | 7 (4.8%)
NV | 8 (5.9%) | 7 (4.8%)
NY | 6 (4.4%) | 7 (4.8%)
OK | 6 (4.4%) | 7 (4.8%)
OR | 4 (2.9%) | 5 (3.4%)
RI | 5 (3.7%) | 5 (3.4%)
TX | 3 (2.2%) | 6 (4.1%)
WV | 8 (5.9%) | 7 (4.8%)
All states | 136 (100%) | 146 (100%)

Note: Ns and percentages include only those that responded to the survey; of those, n = 18 respondents provided testing only, n = 28 respondents provided vaccination only, and n = 118 respondents provided both testing and vaccination.

CBO = community-based organization; FQHC = Federally Qualified Health Center; T/U = Tribal and Urban Indian Organization; LHD = local health department.

Exhibit 1.3 Proportion of each organization type delivering COVID-19 testing versus vaccination (N = 164)

Reported focus | LHDs (n = 40) | FQHCs (n = 31) | CBOs (n = 39) | T/U facilities (n = 23) | Pharmacies (n = 31) | Overall (n = 164)
Promoted or delivered COVID-19 testing | 38 (95.0%) | 31 (100%) | 30 (76.9%) | 20 (87.0%) | 17 (54.8%) | 136 (82.9%)
Promoted or delivered COVID-19 vaccination | 39 (97.5%) | 30 (96.8%) | 30 (76.9%) | 18 (78.3%) | 29 (93.5%) | 146 (89.0%)

Note: Percentages sum to more than 100 because most organizations worked on both testing and vaccination.

Presentation of results. We present all survey data in the exhibits and make comparisons in the text only where there was a difference of at least 10 percentage points, a common practice for evaluating meaningful differences in public health research.^2^ This helps to mitigate the risk that we overemphasize differences based on a limited number of survey responses. Findings may not generalize to all organizations of a given type included in this study or to other organization types. All descriptions of findings refer to organizations that responded to the survey rather than all organizations of a given type. All results are unweighted because findings are exploratory and descriptive, rather than representative of the population of organizations, and we did not test differences for statistical significance. In addition, because the sample is not large and was not random, weighting may present misleading findings by suggesting the results might generalize to a broader set of states and organizations.

Organization of the report. Sections II and III describe strategies, populations served by surveyed organizations, barriers and facilitators to program implementation, and funding sources separately for respondents providing COVID-19 testing and vaccination. Because many respondents promoted or provided testing and vaccination services, they responded to separate survey questions on both testing and vaccination, and their responses are reflected in both sections. Section IV presents results of the survey that were asked of all respondents, regardless of whether they provided vaccination or testing services. When appropriate, we likewise stratify these results by testing versus vaccination. Section V discusses implications of the survey findings for site selection and site visits. Section VI summarizes the survey methods.

1 The definition of the population of focus encompasses groups with medical conditions that increase their risk of infection and adverse outcomes, groups that face greater risk of COVID-19 exposure because of where they live and work, and groups facing barriers to services, such as restrictive work schedules, low transportation access, language barriers, or low levels of income. Throughout this report, we refer to these groups as “populations at disproportionate risk.”

2 See Jewell, N.P. Statistics for Epidemiology (https://nam12.safelinks.protection.outlook.com/?url=https%3A%2F%2Fwww.routledge.com%2FStatistics-for-Epidemiology%2FJewell%2Fp%2Fbook%2F9781584884330&data=05%7C02%7CKBradley%40mathematica-mpr.com%7C3f128003c7fa411e61f108dc105f9aa3%7C13af8d650b4b4c0fa446a427419abfd6%7C0%7C0%7C638403249993935777%7CUnknown%7CTWFpbGZsb3d8eyJWIjoiMC4wLjAwMDAiLCJQIjoiV2luMzIiLCJBTiI6Ik1haWwiLCJXVCI6Mn0%3D%7C3000%7C%7C%7C&sdata=j2e5TbgCqbwMi4wLF8tb1xIae8UXV4kb%2BHhSW7pE89w%3D&reserved=0), 1st Edition. Chapman and Hall/CRC, 2003 .