# Appendix Survey Instrument

The development of the survey instrument was informed by findings from the environmental scan of best practices for delivering COVID-19 vaccination and testing to underserved communities during the pandemic. It contains 25 items including a mix of select-all-that-apply style questions and space for open-ended responses. The first half of the survey asked questions to respondents who indicated they provided testing services, and the second half asked questions to respondents who indicated they provided vaccination services. There was also a set of questions at the end that were administered to all respondents, regardless of whether they provided COVID-19 testing, vaccination, or both.