# 8 REFERENCES

America's Health Insurance Plans, 2019. How Big Pharma Makes Big Profits on Orphan Drugs. [Online] Available at: https://orphandrug.ahip.org/ [Accessed 9 February 2022].
Banawas S., 2018. Clostridium Difficile Infections: A Global Overview of Drug Sensitivity and Resistance Mechanisms. BioMed Research International, p. 8414257. doi: 10.1155/2018/8414257.29682562
Beall R., Hwang T. & Kesselheim A., 2019. Pre-market Development Times for Biologic versus Small-molecule Drugs. Nature Biotechnology, 37(7), pp. 708–711. doi: 10.1038/s41587-019-0175-2.
Bettiol E. O. & Harbarth S. J., 2015. Development of new antibiotics: taking off finally?. Swiss medical weekly, Volume 145.
BiomedTracker, 2016. Clinical Development Success Rates 2006–2015, Washington, DC: Biotechnology Innovation Organization.
Carr A. & Stringer J., 2019. Antibiotic and Antifungal Update September 2019, New York, NY: Needham & Company.
Centers for Disease Control and Prevention, 2019a. Antibiotic Resistance Threats in the United States, Atlanta, GA: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention.
Centers for Disease Control and Prevention, 2019b. About Chronic Diseases. [Online] Available at: https://www.cdc.gov/chronicdisease/about/index.htm
Centers for Disease Control and Prevention, 2021. Antibiotic Use in the United States, 2021 Update: Progress and Opportunities, Atlanta, GA: US Department of Health and Human Services, Centers for Disease Control and Prevention.
Centers for Medicare and Medicaid Services, 2019. Design and Development of the Diagnosis Related Group (DRG). [Online] Available at: https://www.cms.gov/icd10m/version37-fullcode-cms/fullcode_cms/Design_and_development_of_the_Diagnosis_Related_Group_(DRGs).pdf [Accessed 15 November 2021].
CenterWatch, 2019. FDA Approved Drugs. [Online] Available at: https://www.centerwatch.com/drug-information/fda-approved-drugs/
Christensen E., 2007. Methodology of Superiority vs. Equivalence Trials and Non-inferiority Trials. Journal of Hepatology, Volume 46, pp. 947–954. doi:10.1016/j.jhep.2007.02.015.17412447
Clinical Trials Transformation Initiative, 2016. Improving Public Access to Aggregate Content of ClinicalTrials.gov. [Online] Available at: https://aact.ctti-clinicaltrials.org/ [Accessed 202].
Cunha B. R. d., Fonseca L. & Calado C., 2019. Antibiotic discovery: Where have we come from, Where do we go?. Antibiotics (Basel), 8(2), p. 45. doi:10.3390/antibiotics8020045.31022923
Denis A. , 2010. Issues surrounding orphan disease and orphan drug policies in Europe. Applied health economics and health policy, 8(5), pp. 343–350.20804226
Dheman N. , 2021. An Analysis of Antibacterial Drug Development Trends in the United States, 1980–2019. Clinical Infectious Diseases, 73(11), p. e4444–50. doi: 10.1093/cid/ciaa859.32584952
DiMasi J. A., Grabowski H. G. & Hansen R. W., 2016. Innovation in the pharmaceutical industry: new estimates of R&D costs. Journal of health economics, Volume 47, pp. 20–33.26928437
DiMasi J. A., Grabowski H. G. & Hansen R. W., 2016. Innovation in the pharmaceutical industry: New estimates of R&D costs. Journal of Health Economics, Volume 47, pp. 20–33.26928437
DiMasi J., Feldman L., Seckler A. & Wilson A., 2010. Trends in Risks Associated With New Drug Development: Success Rates for Investigational Drugs. Clnical Pharmacology & Therapeutics, 87(3), pp. 272–277.
DiMasi J., Hansen R. G. H. & Lasagna L., 1991. Cost of innovation in the pharmaceutical industry. Journal of Health Economics, Volume 10, pp. 107–142.10113009
DiMasi J., Hansen R. & Grabowski H., 2003. The Price of Innovation: New Estimates of Drug Development Costs. Journal of Health Economics, 22(2), pp. 151–185.12606142
Duke Margolis Center for Health Policy, 2019. Developing Feasible Payment Reform Pathways for Antibiotics to Meet the Needs of Providers, Payers, and the Populations They Serve. s.l.:Duke Margolis Center for Health Policy.
Eastern Research Group, Inc., 2018. Expert Interviews for Incentives to Develop Antibacterial Drugs; Final Report for HHS Office of the Assistant Secretary for Planning and Evaluation, Lexington, MA: Eastern Research Group, Inc..
Eastern Research Group, Inc., 2020. Evaluating the Potential Impacts of Different Clinical Trial Strategies on Drug, Preventitive Vaccine, and Complex Medical Devive Development (Draft), Lexington: s.n.
Fitzhenry D. , 2016. The 2016 Trinity Drug Index, s.l.: Trinity.
Forum on Drug Discovery, Development, and Translation, 2016. Real-World Evidence Generation and Evalutaiton of Therapeutics. s.l., The National Academies of Sciences, Engineering, and Medicine.
Gandhi N. & Schulman K. A., 2021. New Medicare Technology Add-On Payment Could be Used as a Market Support Mechanism to Accelerate Antibiotic Innovation. Health Affairs, 40(12), p. 1926–1934. doi: 10.1377/hlthaff.2021.00062.34871069
GlobalData, 2018. Is the GAIN Act Stimulating Antibiotic R&D?. Pharmaceutical Technology, 19 November, pp. https://www.pharmaceutical-technology.com/comment/gain-act-stimulating-antibiotic-rd/.
Guarga L. , 2019. Implementing reflective multicriteria decision analysis (MCDA) to assess orphan drugs value in the Catalan Health Service (CatSalut). Orphanet journal of rare diseases, 14(1), pp. 1–9.30606190
Harputlugil E., Hayton S., Merrill J. & Salazar P., 2021. First-time Launchers in the Pharmaceutical Industry. [Online] Available at: https://www.mckinsey.com/industries/life-sciences/our-insights/first-time-launchers-in-the-pharmaceutical-industry [Accessed 9 February 2022].
Haute Autorité de santé, 2019. About. [Online] Available at: https://www.has-sante.fr/jcms/c_415958/en/about [Accessed 28 April 2020].
Head S., Kaul S., Bogers A. & Kappetein A., 2012. Non-inferiority Study Design: Lessons to be Learned from Cardiovascular Trials. European Heart Journal, 33(11), pp. 1318–1324, doi: 10.1093/eurheartj/ehs099.22564354
Infectious Diseases Society of America, 2020. IDSA Practice Guidelines. [Online] Available at: https://www.idsociety.org/practice-guideline/practice-guidelines/#/date_na_dt/DESC/0/+/ [Accessed June 2020].
Institute for Clinical and Economic Review, 2018. Chimeric Antigen Receptor T-Cell Therapy for B-Cell Cancers: Effectiveness and Value - Final Evidence Report. [Online] Available at: https://icer.org/wp-content/uploads/2020/10/ICER_CAR_T_Final_Evidence_Report_032318.pdf [Accessed 19 October 2021].
Institute for Clinical and Economic Review, 2020. 2020–2023 Value Assessment Framework. [Online] Available at: https://icer.org/wp-content/uploads/2021/03/ICER_2020_2023_VAF_013120–4-2.pdf [Accessed 19 October 2021].
Institute for Clinical and Economic Review, 2022. Evidence Rating Matrix. [Online] Available at: https://icer.org/evidence-rating-matrix/ [Accessed 8 February 2022].
IQWiG, n.d. Dossier assessments. [Online] Available at: https://www.iqwig.de/en/methods/results/dossier-assessments.3318.html [Accessed 29 April 2020].
Kleijnen S. , 2014b. Standardized reporting for rapid relative effectiveness assessments of pharmaceuticals. International journal of technology assessment in health care, 30(5), pp. 488–496.25747557
Kleijnen S. , 2014a. Piloting international production of rapid relative effectiveness assessments of pharmaceuticals. International journal of technology assessment in health care, 30(5), pp. 521–529.25747562
Krause K., 2019. Post-Approval Economics for New Antibiotics - Presentation. Boston: ASM/ESCMID Conference on Drug Development to Meet the Challenge of Antimicrobial Resistance.
Kristensen F. B. , 2017. The HTA Core Model^®^—10 years of developing an international framework to share multidimensional value assessment. Value in Health, 20(2), pp. 244–250.28237203
Lansdowne L. E., 2020. Exploring the Drug Development Process. [Online] Available at: https://www.technologynetworks.com/drug-discovery/articles/exploring-the-drug-development-process-331894 [Accessed 20 July 2020].
Luepke K. & Mohr J., 2017. The antibiotic pipeline: reviving research and development and speeding drugs to market. Expert Review of Anti-infective Therapy, 15(5), pp. 425–433.28306360
Moore T. J., Heyward J., Anderson G. & Alexander G. C., 2020. Variation in the estimated costs of pivotal clinical benefit trials supporting the US approval of new therapeutic agents, 2015–2017: a cross-sectional study. BMJ Open, Volume 10, p. e038863.
Mulani M. , 2019. Emerging strategies to combat ESKAPE pathogens in the era of antimicrobial resistance: A review. Frontiers in Microbiology, Volume 10, p. 539. doi: 10.3389/fmicb.2019.00539. PMID: 30988669; PMCID: PMC6452778..30988669
Nambiar S., 2019. Overview of Antibacterial Drug Trials. [Online] Available at: https://www.fda.gov/media/133089/download [Accessed 12 March 2021].
National Academies of Sciences, Engineering, and Medicine, 2022. Combatting Antimicrobial Resistance and Protecting the Miracle of Modern Medicine. Washington, DC: The National Academies Press. https://doi.org/10.17226/26350.
Ollendorf D. A. & Pearson S. D., 2017. ICER Evidence Rating Matrix:. [Online] Available at: https://icer-review.org/wp-content/uploads/2016/02/Rating-Matrix-User-Guide-UPDATED-06.30.17.pdf [Accessed May 2020].
PAREXEL International Corp., 2017. PAREXEL Biopharmaceutical R&D Statistical Sourcebook 2017/2018. Newton, MA: PAREXEL International Corp..
Paul S. , 2010. How to Improve R&D Productivity: The Pharmaceutical Industry's Grand Challenge. Nature Reviews: Drug Discovery, 9(3), pp. 203–214.20168317
Peng Z. , 2017. Update on Antimicrobial Resistance in Clostridium difficile: Resistance Mechanisms and Antimicrobial Susceptibility Testing. Journal of Clinical Microbiology, 55(7), pp. 1998–2008. doi: 10.1128/JCM.02250-16.28404671
Petrina M., Cosentino L., Rabe L. & Hillier S., 2017. Susceptibility of Bacterial Vaginosis (BV)-Associated Bacteria to Secnidazole Compared to Metronidazole, Tinidazole and Clindamycin. Anaerobe, Volume 47, p. 115–119. doi: 10.1016/j.anaerobe.2017.05.005.28522362
Piddocck L. J., 2012. The crisis of no new antibiotics—what is the way forward?. The Lancet infectious diseases, 12(3), pp. 249–253.22101066
Plackett B., 2020. Why Big Pharma has Abandoned Antibiotics. Nature, 22 October, pp. S50–S52.
Powers J., 2004. Antimicrobial Drug Development – the Past, the Present, and the Future. Clinical Microbiology and Infection, 10(Supplement 4), pp. 23–31.15522037
Presidential Advisory Council on Combating Antibiotic-resistant Bacteria, 2021. Letter from PACCARB to Xavier Becerra, Secretary of Department of Health and Human Services. [Online] Available at: https://www.hhs.gov/sites/default/files/iasc-draft-letter.pdf [Accessed 7 February 2022].
Renwick M., Simpkin V., Mossialos E. & Organization W. H., 2016. Targeting innovation in antibiotic drug discovery and development: The need for a One Health–One Europe–One World Framework, s.l.: World Health Organization. Regional Office for Europe..
Rex J., Goldberger M., Eisenstein B. & Harney C., 2014. The Evolution of the Regulatory Framework for Antibacterial Agents. Annals of the New York Academy of Sciences, 1323(1), pp. 11–21. doi: 10.1111/nyas.12441.24797794
Schulz L., Kim S., Hartsell A. & Rose W., 2019. Antimicrobial stewardship during a time of rapid antimicrobial development: Potential impact on industry for future investment. Diagnostic Microbiology and Infectious Disease, 95(3), p. 114857. https://doi.org/10.1016/j.diagmicrobio.2019.06.009.31327622
Sciarretta K. , 2016. Economic Incentives for Antibacterial Drug Development: Literature Review and Considerations From the Transatlantic Task Force on Antimicrobial Resistance. Clinical Infectious Diseases, 63(11), p. 1470–1474.27578820
Sertkaya A., Wong H.-H., Jessup A. & Beleche T., 2016. Key cost drivers of pharmaceutical clinical trials in the United States. Clinical Trials, 13(2), pp. 117–126.26908540
Stephens E., 2021. Antibiotics. [Online] Available at: https://www.emedicinehealth.com/antibiotics/article_em.htm [Accessed 28 January 2022].
The International Network of Agencies for Health Technology Assessment, 2020a. Welcome to INAHTA. [Online] Available at: http://www.inahta.org/ [Accessed May 2020].
The International Network of Agencies for Health Technology Assessment, 2020b. HAS – Haute Autorité de Santé. [Online] Available at: http://www.inahta.org/members/has/ [Accessed April 2020].
The International Network of Agencies for Health Technology Assessment, 2020c. NICE – National Institute for Health and Care Excellence. [Online] Available at: http://www.inahta.org/members/nice/ [Accessed April 2020].
The International Network of Agencies for Health Technology Assessment, 2020d. IQWiG – Institut für Qualität und Wirtschaftlichkeit im Gesundheitswesen. [Online] Available at: http://www.inahta.org/members/iqwig/ [Accessed April 2020].
The Pew Charitable Trusts, 2021a. Tracking the Global Pipeline of Antibiotics in Development, March 2021. [Online] Available at: https://www.pewtrusts.org/en/research-and-analysis/issue-briefs/2021/03/tracking-the-global-pipeline-of-antibiotics-in-development [Accessed 28 September 2021].
The Pew Charitable Trusts, 2021b. Antibiotics Currently in Global Clinical Development. [Online] Available at: https://www.pewtrusts.org/en/research-and-analysis/data-visualizations/2014/antibiotics-currently-in-clinical-development [Accessed 28 September 2021].
The Review on Antimicrobial Resistance, 2015. Tackling a global health crisis: initial steps, s.l.: The Review on Antimicrobial Resistance.
Towse A. , 2017. Time for a Change in How New Antibiotics are Reimbursed: Development of an Insurance Framework for Funding New Antibiotics Based on a Policy of Risk Mitigation. Health Policy, 121(10), pp. 1025–1030. doi.org/10.1016/j.healthpol.2017.07.011.28888660
U.S. Bureau of Labor Statistics, 2021. Consumer Price Index for All Urban Consumers: Medical Care in U.S. City Average [CPIMEDSL]. [Online] Available at: https://fred.stlouisfed.org/series/CPIMEDSL#0 [Accessed 28 September 2021].
U.S. Food and Drug Administration, 2016. Non-Inferiority Clinical Trials to Establish Effectiveness - Guidance for Industry, Silver Spring, MD: U.S. Food and Drug Administration, Center for Drug Evaluation and Research.
U.S. Food and Drug Administration, 2018. NDA and BLA Calendar Year Approvals. [Online] Available at: https://www.fda.gov/Drugs/DevelopmentApprovalProcess/HowDrugsareDevelopedandApproved/DrugandBiologicApprovalReports/NDAandBLAApprovalReports/ucm373413.htm
U.S. Food and Drug Administration, 2018. Prescription Drug User Fee Rates for Fiscal Year 2019. Docket No. FDA-2017-N-0007 ed. s.l.:Federal Register.
U.S. Food and Drug Administration, 2018. Priority Review. [Online] Available at: https://www.fda.gov/patients/fast-track-breakthrough-therapy-accelerated-approval-priority-review/priority-review [Accessed 9 March 2021].
U.S. Food and Drug Administration, 2018. Qualified Infectious Disease Product Designation Guidance for Industry - Questions and Answers. [Online] Available at: https://www.fda.gov/media/111091/download [Accessed 20 June 2020].
U.S. Food and Drug Administration, 2018. Report to Congress: Generating Antibiotic Incentives Now, Washington, DC: U.S. Department of Heath and Human Services, Food and Drug Administration.
U.S. Food and Drug Administration, 2018. The Drug Development Process. [Online] Available at: https://www.fda.gov/patients/learn-about-drug-and-device-approvals/drug-development-process [Accessed 17 July 2020].
U.S. Food and Drug Administration, 2019. Drugs@FDA: FDA Approved Drug Products. [Online] Available at: https://www.accessdata.fda.gov/scripts/cder/daf/ [Accessed 10 October 2019].
Van Wilder P. B., Bormans V. V. & Dupont A. G., 2013. Relative efficacy and effectiveness assessment of new pharmaceuticals in three EU member states: current practices and outcome agreement between Belgium, the Netherlands and France. European journal of clinical pharmacology, 69(12), pp. 2037–2043.23995947
Wagner M. , 2016. Can the EVIDEM framework tackle issues raised by evaluating treatments for rare diseases: analysis of issues and policies, and context-specific adaptation. Pharmacoeconomics, 34(3), pp. 285–301.26547306
White A.R. on behalf of the BSAC Working Party on The Urgent Need: Regenerating, 2011. Effective antibacterials: at what cost? The economics of antibacterial. Journal of Antimicrobial Chemotherapy, 66(9), p. 1948–1953.21700625
Wong C., Siah K. & Lo A., 2019. Estimation of Clinical Trial Success Rates and Related Parameters. Biostatistics, 20(2), pp. 273–286.29394327
World Health Organization, 2017. WHO publishes list of bacteria for which new antibiotics are urgently needed. [Online] Available at: https://www.who.int/news/item/27-02-2017-who-publishes-list-of-bacteria-for-which-new-antibiotics-are-urgently-needed [Accessed 9 March 2021].
World Health Organization, 2019. Antibacterial Agents in Clinical Development: An Analysis of the Antibacterial Clinical, Geneva, Switzerland: World Health Organization.
World Health Organization, 2019. Antibacterial Agents in Preclinical Development: An Open Access Database, Geneva, Switzerland: World Health Organization.
Wouters O., McKee M. & Luyten J., 2020. Estimated Research and Development Investment Needed to Bring a New Medicine to Market, 2009–2018. JAMA, 323(9), p. 844–853. doi:10.1001/jama.2020.1166.32125404
Zelei T., Molnár M. J., Szegedi M. & Kaló Z., 2016. Systematic review on the evaluation criteria of orphan medicines in Central and Eastern European countries. Orphanet Journal of Rare Diseases, 11(1), pp. 1–11.26728142