# EXECUTIVE SUMMARY

In 2017, at least 2.8 million people in the U.S. acquired serious infections with bacteria that are resistant to one or more antimicrobial drugs and 35,000 have died as a result. Resistance to antimicrobials is viewed as a global threat with antimicrobial drug use in human and animal health driving resistance. Compounding the problem is an insufficiently robust global antimicrobial drug pipeline which currently includes a total of 43 antimicrobial compounds in different stages of development with only 15 showing promise against pathogens showing resistance to most of the antimicrobials available. There are over 100 antimicrobial drugs that are used to treat a variety of bacterial diseases at present (Powers, 2004; Stephens, 2021). However, without the development of new drugs, expansion of resistance will continue to reduce the effectiveness of currently available antimicrobial drugs and leave many patients with few, if any, treatment options. Stakeholders have proposed that pharmaceutical companies are avoiding antimicrobial drug development because they anticipate poor market performance (i.e., low sales revenues) for these drugs.

This study examines how recently approved antimicrobial drugs are performing relative to their added clinical benefit and the contributing factors to this performance compared to other types of drugs. Using public and proprietary data sources coupled with expert interviews, we estimate the development cost and comparative added clinical benefit of a total of 32 drugs (Table E - 1) of which 12 are antimicrobials (AM cohort), 14 are oncology drugs (oncology cohort), and the remaining 6 are other types of drugs that are similar to antimicrobials with respect to certain characteristics such as treatment duration and DRG-style^1^ reimbursement (non-AM comparator cohort). We then compare the comparative added clinical benefit of each drug to its market performance within each drug cohort.

Table E - 1 Drugs Selected for Analysis

AM Cohort Drugs | Non-AM Comparator Cohort Drugs | Oncology Cohort Drugs
Avycaz | Bridion | Erivedge
Baxdela | Giapreza | Ibrance
Dalvance | Lokelma | Portrazza
Nuzyra | Surfaxin | Braftovi
Orbactiv | Veltassa | Darzalex
Sivextro | Vistogard | Vitrakvi
Teflaro | | Rubraca
Vabomere | | Jevtana
Vibativ | | Yondelis
Xerava | | Cometriq
Zemdri | | Zelboraf
Zerbaxa [a] | | Stivarga
| | Cyramza

We find that the drugs in the AM cohort have average to high development and approval costs when compared to the non-AM comparator and oncology cohort drugs. However, once cost of failures and opportunity cost of capital are accounted for, drugs in the AM cohort have the lowest expected capitalized development and approval costs of $1,508 million on average, which is less than that estimated for drugs in the non-AM comparator ($3,198 million) and oncology ($6,293 million) cohorts. In other words, compared to those drugs in the non-AM comparator and oncology cohorts, AM cohort drugs are the least costly to develop and obtain regulatory approval for.

Using a series of evaluation metrics garnered from different information sources, such as European health technology assessments (HTAs), Trinity Drug Index, and others (Table E - 2), we rank each drug compared to the others in the same cohort using an iterative process with a weighting routine. We then calculate the overall comparative added clinical benefit score for each drug within each cohort which provides more of a qualitative ranking. Drugs with high comparative added clinical benefit include Zerbaxa, Avycaz, Vabomere, and Sivextro in the AM cohort, Veltassa and Lokelma in the non-AM comparator cohort, and Rubraca, Zelbograf, Ibrance, and Erivedge in the oncology cohort.

Table E - 2 List of Evaluation Metrics Used in Assessing Comparative Added Clinical Benefit

Evaluation Metric | AM Cohort Drugs | Non-AM Comparator Cohort Drugs | Oncology Cohort Drugs
New Molecular Entity | ✓ | ✓ | ✓
New Chemical Entity | ✓ | ✓ | ✓
Route of Administration | ✓ | ✓ | ✓
Annual Number of U.S. Cases | | ✓ | ✓
Estimated Market Size | ✓
Number of Drugs for Indication | ✓ | ✓ | ✓
Activity against ESKAPE Pathogens | ✓
Activity against CDC urgent WHO critical pathogens | ✓
Trinity Drug Index Therapeutic Score | ✓ | ✓ | ✓
Trinity Drug Index Commercial Score | ✓ | ✓ | ✓
Trinity Drug Index R&D Score | ✓ | ✓ | ✓
HAS Actual Clinical Benefit (ACB) | ✓ | ✓ | ✓
HAS Clinical Added Value (CAV) | ✓ | ✓ | ✓
NICE | ✓ | ✓ | ✓
IQWiG | ✓ | ✓ | ✓
Automated AST Device Incorporation | ✓
QDIP Designation | ✓
BARDA Funding | ✓
P&T Community Decision | ✓ | ✓ | ✓
IDSA Guideline Inclusion | ✓ | ✓
ICER Assessment | | | ✓
Medicaid Coverage in Top Ten Largest Medicaid Markets [a] | ✓ | ✓ | ✓

HAS = Haute Autorité de Santé

NICE = National Institute for Health and Care Excellence

IQWIG = Institute for Quality and Efficiency in Health Care

AST = Antimicrobial Susceptibility Test

QDIP = Qualified Infectious Disease Product

BARDA = Biomedical Advanced Research and Development Authority

P&T = Pharmacy & Therapeutics

IDSA = Infectious Diseases Society of America

ICER = Institute for Clinical and Economic Review

[a] The top ten Medicaid markets include California, New York, Texas, Pennsylvania, Florida, Ohio, Illinois, Massachusetts, Michigan, and New Jersey.

We then evaluate the market performance for all drugs selected using quarterly sales data from IQVIA MIDAS and compare this performance against the comparative added clinical benefit estimated for each drug. Our analysis indicates that there is a direct relationship between market performance defined as nine quarters of cumulative global sales since market launch and comparative added clinical benefit within each cohort. In other words, drugs with higher overall comparative added clinical benefit scores tend to have higher early market sales compared to other drugs in the same cohort on average, although there are a few exceptions. While this relationship holds across all three drug cohorts examined here, the magnitude of sales is exponentially higher for the oncology cohort drugs than those in the AM and non-AM comparator cohorts. The average cumulative 9 quarter sales for the highest-ranking AM and non-AM comparator drugs are $42 million and $62 million, respectively, and $1,041 million for the oncology drugs.

Overall, this analysis shows that markets do in fact reward comparative added clinical benefit within each therapy area (i.e., bacterial infections, cancer, etc.). However, there are large discrepancies in commercial market performance (i.e., magnitude of sales revenue) among different therapy areas that reflect inherent differences in patient populations, treatment durations, the setting in which these drugs are used (outpatient versus inpatient), and DRG-based reimbursement that incentivizes cost containment in hospitals.

1 A diagnosis-related group (DRG) is a patient classification system that Medicare uses to classify costs associated with a given inpatient hospital stay and determines how much to reimburse for those hospital stays. Under this system, Medicare pays a predetermined amount based on the patient’s DRG instead of “pay[ing] the hospital for each specific service it provides” (Centers for Medicare and Medicaid Services, 2019).