# DISCLAIMER

This report was prepared by ERG, under contract to the Office of the Assistant Secretary for Planning and Evaluation (ASPE). The findings and conclusions of this report are those of the author(s) and do not necessarily represent the views of ASPE, Administration for Preparedness and Response (ASPR), Centers for Disease Control and Prevention (CDC), National Institutes of Health (NIH), Food and Drug Administration (FDA) or U.S. Department of Health and Human Services (HHS).