# 7 DISCUSSION AND CONCLUSION

Looking at the results of the development cost, comparative added clinical benefit, and market performance analyses can help us form a picture of the overall market returns for current and future AM drugs.

We see that the development costs in each cohort vary significantly by drug, but the median expected capitalized development and approval costs were highest for oncology drugs ($3,123.6 million dollars) and lowest for AM drugs ($1,507.0 million). However, the mean and median of the cumulative first 9 quarters of sales for drugs in the oncology cohort were $587.89 and $271.80 million, but only $34.43 and $28.07 million for the AM cohort of drugs. If the cost of developing an AM drug is about a factor of 2 less than an oncology drug, but the returns are nearly a factor of 10 less than an oncology drug in the first year, this would corroborate the concern of many manufacturers and experts that the relatively poor returns on investment for AM drugs make it very difficult to sustainably bring new drugs to market (Rex 2014, Piddock 2011, Stergiopoulos 2018, Duke Margolis Center for Health Policy 2019). As discussed in Section 4.4, when we account for the variety of push incentives, such as R&D grants through U.S. government and other public-private partnership programs that several recent AM drug developers have benefited from, the estimated development and approval costs for select AM drugs are significantly lower than those drugs in the non-AM comparator and oncology cohorts, for which similar incentives are not available. If such incentives have the potential to reduce development costs incurred by the drug developers between 80 to 90 percent, then developing an AM drug, on average, is more than 13 (= $3,123.6 million / [(1– 0.85 percent) × $1,507.0 million]) times cheaper compared to an oncology drug to the developer. Then, one can also argue that the slow market uptake and low returns in early years of marketing may not be as detrimental from the same perspective. When evaluating the cost of drug development from a societal perspective, the source of funding is irrelevant. That said, the goal of this study is to evaluate the returns to the drug manufacturer. In that sense, it does matter who incurs these costs. Grants that do not have to be paid back offset private costs and thereby improve drug developer returns significantly. However, this improvement in overall returns may still be insufficient to keep a small developer that is dependent on the revenues from a single marketed drug financially viable or desirable as an acquisition target by big pharma.

Interestingly, the viability of non-AM comparator cohort of drugs appears to be very similar to the AM cohort. The non-AM comparator cohort of drugs had, on average, higher development costs than the AM cohort, and low early market sales at $34.49 (average) and $33.07 million (median). It does, however, appear that AM drugs and non-AM comparator drugs that are used in inpatient settings and thus are subject to DRG-based reimbursement both suffer from low revenues compared to oncology drugs.

Due to limitations of only using the first 9 quarters of sales data and small sample sizes, the relationship between added clinical benefit and early market sales is not very robust. However, the data show that overall, drugs with higher overall comparative added clinical benefit scores tend to have higher early market sales compared to other drugs in the same cohort on average. There are, however, exceptions to this. For example, in the oncology cohort, Darzalex, a multiple myeloma drug, has an overall comparative clinical benefit score of 162 which is 14 points higher than that of Rubraca, a drug for recurrent ovarian and metastatic prostate cancers, but has first 9 quarter sales of $1,710 million which is $1,691 million higher than that of Rubraca. This could partly be due to the ordinal ranking method we employed which accounts for whether a drug X ranks higher/lower than a drug Y in the same cohort but not by how much higher/lower. In other words, drug X with an annual patient population estimate of 100,000 could receive a rank of 3, followed by drug Y with a rank of 4 and an annual patient population estimate of 5,000, and drug Z with a rank of 5 and an annual patient population estimate of 1,000. In this example, even though drug X’s market size is 20 and 100 times larger than that of drugs Y and Z, respectively, its ranking does not reflect the large difference in the evaluation metric estimates. Even with this limitation, however, we observed that in each cohort, the drug with the highest cumulative 9-quarter sales was categorized into the high comparative added clinical benefit group consistently (Table 17). This indicates that our comparative added clinical benefit assessment algorithm is relatively robust and informative.

Overall, our analysis shows that the early market returns do seem to reflect the overall comparative added clinical benefit of the drug compared to other drugs in the market within each cohort examined. There are exceptions to this, however, in all three cohorts as noted above. It is not, however, possible to infer whether oncology drugs have better market performance because they are of higher added clinical benefit than AM and non-AM comparator drugs. The notable difference in market performance for oncology drugs is likely due to several factors. First, oncology drugs are not subject to the DRG-based reimbursement that keeps pricing for drugs administered in the hospital setting (i.e., Part A drugs) such as the AM and non-AM comparator drugs, in check. Second, the treatment durations for oncology drugs are much longer than those for AM and non-AM comparator drugs with many patients remaining on these medications for years. Third, patient populations for most of the oncology drugs in this cohort also are larger than most AM drugs. For example, the estimated number of metastatic locally advanced basal cell carcinoma cases that Erivedge is approved to treat is close to 3 million annually whereas the number complicated urinary tract infections that can be treated by Zemdri is only around 30,000 per year.

There is significant heterogeneity in commercial market performance among different therapy areas that reflect differences in patient populations, treatment durations, where these drugs are used (outpatient versus inpatient), and DRG-based reimbursement that incentivizes cost containment in hospitals. Despite this heterogeneity, our analysis suggests that markets tend to reward comparative added clinical benefit within each therapy area (e.g., bacterial infections, cancer, etc.) but that the value ascribed to that benefit per patient and per population vary by at least an order of magnitude between DRG price limited Part A drugs (AM and non-AM) and protected class, usually Part B, drugs (oncology).

Additional research following on this analysis could explore the post approval costs that developers incur to conduct additional studies in pediatric and special adult populations, surveillance, pharmacovigilance, marketing, and manufacturing, relative to the product sales revenues generated in the same time frame. Gaining a better understanding of the relationship between post approval costs and product sales revenues could help further inform the discussion of “pull” incentives for AM drugs. Another avenue for future research could be to extend the comparative added clinical benefit assessment methodology to additional types of products to test the robustness of the relationship between comparative added clinical benefit and product sales. Understanding the future economic burden of AMR would also help to evaluate the strengths and weaknesses of the existing pipeline of AM drugs, and the potential need for additional incentives.