# 6 MARKET PERFORMANCE ANALYSIS

The last component to garnering a comprehensive view on the markets for the three drug cohorts was to investigate their relative commercial performance. After determining the comparative added clinical benefit of each drug, we hypothesized that in general, if markets function as expected, drugs with higher added clinical benefit relative to other drugs in the same cohort would perform better in the market upon launch and beyond.

As noted previously, AM drugs face unique challenges both before and after market entry. First, antimicrobial stewardship has resulted in decreased prescribing of AM drugs in general, but especially for newer drugs because they are often reserved for last-line treatment. Even among those that do get prescribed, many are only prescribed for short-term use, stifling any significant market returns (Duke Margolis Center for Health Policy, 2019; Rex, et al., 2014; Piddocck, 2012). Moreover, physicians often prefer prescribing less expensive generic drugs, especially when new AM drugs are approved based on noninferiority instead of superiority trials (Duke Margolis Center for Health Policy, 2019; Luepke & Mohr, 2017). The diagnostic-related group (DRG) based reimbursement system in the inpatient setting further incentivizes the use of older cheaper generic versions of the AM drugs.

All of these factors have contributed to the reported slow market uptake for new AM drugs in recent years. In their most recent report, Carr and Stringer (2019) referred to the sales of several AM drugs that entered the market in 2018 as being mostly ‘disappointing’. In the analysis described below, we pull international sales data on all of the drugs to analyze whether the sales for the drugs in the AM cohort are lower than the other cohorts and not reflective of their comparative added clinical benefit.

## 6.1 METHODOLOGY AND DATA SOURCES

### 6.1.1 IQVIA MIDAS Database

We used IQVIA MIDAS data to examine the global sales of each drug selected. The IQVIA MIDAS database includes estimates of all drugs sold (in dollars and units) directly from drug manufacturers and indirectly through wholesalers into retail and non-retail channels of distribution in over 90 countries’ healthcare markets. The database is considered the industry standard for measuring pharmaceutical sales. The data measures sales at actual transaction prices but does not capture off-invoice discounts, such as rebates to plans or pharmacy benefit managers (PBMs) in the U.S., that reduce the amount of money received by manufacturers. IQVIA uses a proprietary algorithm that relies on regional-, sectoral-, and distribution-channel-specific factors to project total global sales volume from the sample of data that they collect on a regular basis.

We obtained a custom tabulation from the MIDAS database for each drug in our cohorts, querying by generic name to identify any international sales under a different trade name. The data included quarterly sales (in $ US, kilograms, and units) for each drug by country from Q1 2007 through Q1 2021. Some products had sales in Europe before FDA approval for the U.S. market, meaning that some products had sales before 2010, the earliest starting in Q1 of 2007. However, most drugs saw U.S. sales one to two quarters after obtaining FDA approval.

### 6.1.2 Comparing Sales Against Overall Added Clinical Benefit Score

After collecting all relevant sales data for the drugs, we aimed to test our hypothesis that drugs with higher comparative added clinical benefit scores would generally have better market sales by plotting the sales of each drug against its overall comparative added clinical benefit score. While the overall comparative added clinical benefit score is not a stand-alone measure of the real-world clinical benefit of a drug over other therapies, the score embodies the comparative clinical value of each drug, based on our added clinical benefit framework, to compare to sales. We note that the added clinical benefit scores are not comparable across the three cohorts.

Given that each drug has been on the market for a different length of time, we needed to normalize sales using a standard length of time to appropriately compare the drugs in a given cohort. The duration for those drugs that have been on the market for the shortest amount of time as of Q1 2021 (Nuzyra and Yescarta) among all drugs included in this analysis was 9 quarters. Thus, we calculated each drug’s first 9 quarters of sales to normalize our sales variable before comparing this value to the drug’s overall comparative added clinical benefit score. There are a variety of factors, such as the number of countries the drug is approved and marketed in, that influence a drug’s market uptake, and hence its market success during the initial couple of years post launch. To smooth out those differences, the ideal comparison is between a drug’s peak-year sales, the level at which the sales plateau, to its overall comparative added clinical benefit score. An example of peak-year sales can be seen for Teflaro in Figure 7 below. The first 16 quarters of sales show growth in each quarter, and then after Q17, the sales appear to even out and fluctuate between $36 and $42 million. Since data were unavailable for peak-year sales for all of the drugs selected, we used total first 9 quarter sales as a proxy. Table 18 presents the mean and median 9 quarter sales values as well as their range across the drugs in each cohort. On average, the sales are similar for the drugs in the non-AM comparator cohort and the AM cohort drugs. In contrast, oncology cohort drug first 9 quarter sales are exponentially higher on average than the drugs in the AM and non-AM comparator cohorts.

Table 18 Descriptive Statistics of First 9 Quarters IQVIA MIDAS Sales (in $ Million) for AM, Non-AM Comparator, and Oncology Cohort Drugs

Drug Cohort | Mean ($ millions) | Median ($ millions) | Range ($ millions)
AM | $34.43 | $28.07 | $1.24 (Zemdri) - $75.79 (Avycaz)
Non-AM Comparator | $34.49 | $33.07 | $0.57 (Surfaxin) - $88.02 (Lokelma)
Oncology | $587.89 | $271.80 | $18.21 (Rubraca) - $3,551.16 (Ibrance)

After plotting the total of the first 9 quarters of sales against the overall comparative added clinical benefit score for each cohort of drugs, we fit an exponential line to the data. Similar to the sensitivity analysis related to European HTAs described in Section 5.1.3, we repeated the fit both with and without HTA data. These exponential fits are meant to serve as visual guides to help evaluate the relationship between sales and comparative added clinical benefit. Partly due to our small sample sizes, it is not feasible to conduct a rigorous statistical analysis to estimate this relationship. Thus, we only report the simple Pearson correlation coefficients between 9-quarter sales and overall comparative added clinical benefit scores in the graphical displays.

## 6.2 RESULTS

### 6.2.1 Quarterly Global Sales Since Launch

The quarterly sales, summed globally, are shown in Figure 7 (not cumulative). Q1 represents the first quarter the drug was on the market, so drugs approved more recently will have fewer quarters of data available.

The first thing to note about these three figures is the differences in scales on the y-axis. The highest sales in one quarter for the AM cohort were $99.54 million for Avycaz in its 24^th^ quarter on the market, which was Q1 2021. Most other AM drugs reached between $5 and $10 million in quarterly sales after 1–2 years and up to $10 to $40 million in quarterly sales after about 5 years on the market. While Avycaz’s sales were still much lower than the non-AM comparator cohort drug Bridion’s with $311.77 million in sales in its 51^st^ quarter (i.e., Q1 2021), the rest of the non-AM comparator cohort had sales comparable to the AM cohort in the first 1–2 years on the market. However, the non-AM comparator cohort, excluding Bridion, have more recently approved drugs than the AM cohort and thus fewer years of data, but Veltassa does surpass $40 million in quarterly sales after its 4^th^ year on the market. The sales for many drugs in the oncology cohort dwarf the sales for those in the other two cohorts. The highest quarterly sales for the oncology cohort were $1,515.75 million for Ibrance in its 21^st^ quarter (i.e., Q1 2020). The first 1–2 years on the market for many oncology drugs saw quarterly sales up to $20 - $50 million while the top performing drugs soared up to $100 to $1000 million.

Figure 7 Quarterly Global Sales Since Launch (in $ Million) for AM, Non-AM Comparator, and Oncology Cohort Drugs as Reported in IQVIA MIDAS

The series of graphs depict the quarterly sales since launch for AM, non-AM comparator, and oncology cohort of drugs over time.

Nearly all drugs in all three cohorts showed increasing sales by quarter through the end of the available years of data; indicating that these data likely miss the period of ‘peak-year sales,’ or the maximum annual sales a drug will reach before plateauing/decreasing as other drugs populate the market. Depending on the indication and the availability of other drugs for that indication, the peak-year sales may come a few years after approval, e.g., Vibativ, which stabilized at around $5 million 27 quarters after entering the market before decreasing around quarter 37. On the other hand, a drug may not reach peak-year sales for many years, as in the case of Bridion, which continue to increase sharply through 51 quarters on the market. Even though many of the drugs in this analysis have not reached their peak-year sales yet, the available data reveal the relative magnitude of average sales among the three cohorts. We also note that the effects of the COVID-19 pandemic in 2020, which may have affected the sales trajectories of not only AM but all drugs, were not considered for this analysis.

### 6.2.2 First 9 Quarters of Sales versus Overall Comparative Added Clinical Benefit Scores

Figure 8 through Figure 10 below present the cumulative 9 quarters of global sales since launch for each drug against the overall comparative added clinical benefit score we assigned in our analysis both with and without HTA data. We also fit a trend line to visually depict the relationship between sales and comparative added clinical benefit. The x-axis in Figure 8 through Figure 10 has been flipped for legibility because in our analysis, lower scores reflect higher added clinical benefit.

Within the AM cohort, drugs with higher overall comparative added clinical benefit scores tend to have higher early market sales. The trend lines for both analyses with and without HTA data show this correlation between overall comparative added clinical benefit score and cumulative sales from the first 9 quarters on the market. Given the small sample size, however, the estimated fits for all cohorts are not very robust and have large confidence bounds around the parameter estimates as expected. Both the non-AM and oncology cohorts followed the same trend observed for AM drugs. The trend lines for these cohorts both with and without HTA data show a positive correlation between higher comparative added clinical benefit (i.e., lower overall score) and higher cumulative sales during the first 9 quarters on the market, indicating that the HTA evaluation compared to our score did not provide additional explanatory power. The results show that the drug with the highest first 9 quarters of sales was consistently placed in the high comparative added clinical benefit group for all three cohorts and in all sensitivity analyses. However, while the overall trend was present when each cohort was analyzed collectively, there were still numerous outliers or drugs that did not display the relationship between added benefit and sales. For example, Veltassa and Rubraca had uncharacteristically low early market sales when compared to the rest of the non-AM and oncology cohorts, respectively. Rubraca and Ibrance are both ranked very highly in the oncology cohort, but these two drugs also represent the lowest and highest first 9 quarters of sales in the oncology cohort, respectively. We were not able to identify a definitive cause for Rubraca and Veltassa’s low sales, but the case of Veltassa does highlight the limitations of using only the first 9 quarters of sales data. From Figure 7, Veltassa’s quarterly sales start increasing at a faster rate after the first year, while Vistogard, with the lowest overall comparative clinical benefit score, continues to have very low sales for the next few years.

## 6.3 LIMITATIONS

This analysis was limited by lack of sales data over sufficiently long time period. From Figure 7, we see that most drugs take a few years for their sales to stabilize in the market. Even then, many of the drugs in our cohorts do not appear to have reached their peak-year sales within the years of available data from IQVIA. Therefore, since we were only able to use data from the first 9 quarters of sales, any trends in the data should be viewed with this caveat.

Figure 8 First 9 Quarters of IQVIA MIDAS Reported Sales versus Overall Comparative Clinical Benefit Score – AM Cohort

Figure 9 First 9 Quarters of IQVIA MIDAS Reported Sales versus Overall Comparative Clinical Benefit Score – Non-AM Comparator Cohort

Figure 10 First 9 Quarters of IQVIA MIDAS Reported Sales versus Overall Comparative Clinical Benefit Score – Oncology Cohort

## 6.4 SENSITIVITY ANALYSIS

Several researchers noted that drugs marketed by large biotechnology companies tend to have better sales than those marketed by small companies. Large companies have significantly more financial resources, well-trained large sales teams, global presence, and knowhow to navigate marketing and reimbursement requirements in different regions of the world. All of these factors can affect market uptake of new drugs. A recent analysis by McKinsey & Company (2021) evaluated the success of product launches between 101 experienced and 28 first-time launchers for drugs approved by FDA from 2014 through 2017. They found that 39 percent of first-time launchers exceed analysts’ prelaunch sales forecasts, compared to 49 percent of experienced launchers. While this difference is not sizable, it could be significant. Therefore, we conducted a sensitivity analysis to see if company size alters the relationship between overall comparative added clinical benefit score and first 9-quarters sales across all three drug cohorts. For the oncology cohort, we performed an additional sensitivity analysis where we examined whether orphan drug designation influences this relationship. Drugs that receive orphan status receive seven years of marketing exclusivity, waiver of PDUFA fees, and a 25 percent tax credit for clinical costs incurred for the development of the drug. A study by America’s Health Insurance Plans (2019) found that orphan drugs were 25 times more expensive than other drugs. Since 9 out of the 13 drugs in the oncology cohort were orphan drugs, we wanted to see if we would observe a different relationship between overall comparative added clinical benefit score and first 9 quarters of sales within this subset.

Figure B - 1 through Figure B - 6 in Appendix B present the results of our sensitivity analysis. We find that the relationship between overall comparative added clinical benefit score and first 9 quarters of sales is fairly robust; drugs with higher overall comparative added clinical benefit scores tend to have higher early market sales on average.