# 5 EVALUATION OF COMPARATIVE ADDED CLINICAL BENEFIT

Clinical efficacy measures whether a drug treated patients as intended in a clinical trial. In contrast, comparative clinical effectiveness, which is the added clinical benefit of the drug over existing treatments, is revealed once the drug demonstrates improved health outcomes over existing treatments with widespread use after approval and accounting for ‘real-world’ conditions such as patients with multiple co-morbidities who may be taking multiple medications (Institute for Clinical and Economic Review, 2020). Real-world evidence, which FDA defines as health care data that is taken from sources outside traditional clinical settings, such as evidence generated from post-approval studies in more typical clinical settings and expanded patient populations, is revealed through a multitude of sources in the years after drug approval including consumer data, electronic health records and mortality data, and disease registries (Forum on Drug Discovery, Development, and Translation, 2016).

Prior to marketing approval, the added clinical benefit of a drug can be evaluated using pivotal clinical trials designed to demonstrate superiority (i.e., the drug is [underlined: better than] the standard therapy) rather than one designed to demonstrate non-inferiority (i.e., the drug is [underlined: not worse than] the standard therapy). For any drug, superiority trials require larger patient enrollment which makes them more costly to conduct. In some cases, such as an AM drug designed to treat highly resistant infections, superiority trials might be infeasible or unethical to conduct due to lack of patients or knowingly providing inferior treatments. In the absence of superiority trials, the evidence for the added clinical benefit of a drug, as defined here, is accumulated through actual use over time post approval. Since demonstration of superiority is not mandatory for regulatory approval, all of the Phase 3 trials submitted in support of an NDA for the drugs in our AM cohort have used noninferiority designs.

After clinical efficacy has been demonstrated in Phase 3 trials and the drug enters the market upon regulatory approval, real-world data may be collected over the following years that can be used to inform future clinical and policy decisions. However, public and private insurers, physicians, hospital pharmacy and therapeutics committees, and others need to make decisions regarding the drug’s use, reimbursement, and formulary placement either at or soon after drug approval when there is still limited evidence of the drug’s added clinical benefit. In the absence of standardized comparative drug evidence generation and assessments, these decisions may rely on individual practitioner’s idiosyncratic experience with and perceptions of the drugs (Forum on Drug Discovery, Development, and Translation, 2016). To combat this, several organizations, primarily non-U.S. government agencies, currently conduct health technology assessments, also referred to as clinical value assessments, to aid their decision making around drug policy or pricing. These assessments basically add an economic and treated population estimate overlay on the regulatory efficacy data by compiling existing information but do not generate any new data.

To gain a better understanding of the methods used in such assessments, we conducted a focused review of literature related to clinical value assessments and real-world effectiveness that was completed on February 1, 2021. For the review, we queried PubMed using search terms, such as “clinical effectiveness assessment,” “real-world effectiveness assessment,” “added clinical benefit, “ and “clinical added value.” To target our search, we limited the search query to the title and/or abstract of papers with these key words and applied further search filters to only return literature published between 2010 and 2021 and only search within these article types^25^: Books and Documents; Journal Article; Meta-Analysis; Practice Guideline; Research Support, NIH Extramural; Research Support, NIH Intramural; Research Support, Non-U.S. Government; Research Support, U.S. Government, Non-Public Health Service (PHS); Research Support, U.S. Government, PHS; Research Support, U.S. Government; Review; and Systematic Review.

Our literature search yielded 155 studies. We supplemented these studies with The International Society for Pharmacoeconomics and Outcomes Research’s (ISPOR) Value Assessment Frameworks Initiative Reports, as well as through a forward citation search of the literature results. From this set of literature, we reviewed the study abstracts to narrow down the collection to only the most relevant studies that described existing clinical value assessments or provided theoretical discussion of value assessment frameworks. This review resulted in 30 relevant studies that merited further in-depth review. Of these, 11 studies were either deemed irrelevant or did not have full study texts available. Many of the remaining 19 studies discussed the use of clinical value assessments to aid pricing and reimbursement decision-making for pharmaceuticals. The following discussion summarizes the findings of these 19 studies.

Many international assessments employed what they referred to as Relative Effectiveness (RE) Assessments, which compared the achieved health outcomes of a drug to comparator treatment options (Kleijnen, et al., 2014b). These assessments consequently both measured the real-world effectiveness of a drug, and, as we try to capture in our assessment, whether the drug is valuable relative to other therapy options, i.e., whether the drug has added clinical benefit over existing treatments. Our assessment methodology below places explicit value on drugs that either fill an unmet need or achieve better outcomes than the standard therapy.

In Europe, clinical value assessments are primarily addressed using the Health Technology Assessment (HTA) Core Model®. The HTA Core Model®, was originally developed by stakeholders including patients, providers, payers, and the European Commission to facilitate standardized value assessments for new health technologies in Europe. It consists of a set of generic questions that fall into the categories: 1) health problem and current use of the technology, 2) description and technical characteristics of the technology, 3) safety, 4) clinical effectiveness, 5) costs and economic evaluation, 6) ethical analysis, 7) organizational aspects, 8) patient and social aspects, and 9) legal aspects. The model is designed to allow assessors, who may be drug reimbursement or other therapy decision makers, to choose the questions most relevant to their assessment from the 136 provided. The model then provides methodological guidance so the assessors can answer each question and summarize the findings into ‘result cards.’ These results are structured to highlight information on the value of the technology of interest that is most useful for decision making (Kleijnen, et al., 2014a; Kleijnen, et al., 2014b; Kristensen, et al., 2017).

Another pervasive theme in other value assessment approaches in use was that the challenges assessing added clinical benefit for orphan drugs appeared similar to those for AM drugs in that both types of drugs usually target small populations; there often is limited added clinical benefit evidence at time of marketing authorization and developing; and using these drugs is often not cost-effective (Denis, et al., 2010; Zelei, et al., 2016; Van Wilder, et al., 2013). For example, a general clinical value assessment may not assign a high score to an AM drug approved for a relatively rare indication (i.e., MDR pneumonia) because the assessment may find it to be too expensive, especially in the presence of stewardship measures that result in infrequent prescriptions.

A selection of the literature also suggested methods to assess added clinical benefit more accurately in orphan drugs. The most common method from the literature reviewed was the use of reflective multicriteria decision analysis (MCDA). MCDA refers to an analytical method that uses input from a wide set of data metrics, or criteria, and is useful for contextualizing a set of disparate data elements. For example, cost effectiveness may be one criterion, but the full analysis may include many other criteria, such as unmet clinical need, that provide more context from different perspectives. Since MCDAs allow for a multitude and variety of criteria, this methodology has been shown to be responsive to rare disease issues (Wagner, et al., 2016; Guarga, et al., 2019). Other strategies to assess orphan drugs included weighing certain factors, such as the treatment innovation and unmet need, more highly than others, such as the patient population size, the cost effectiveness, the quality of evidence and clinical practice guidelines (Guarga, et al., 2019; Zelei, et al., 2016; Denis, et al., 2010).

## 5.1 METHODOLOGY AND DATA SOURCES

We developed a comparative added clinical benefit evaluation methodology that draws on publicly available data and encapsulates factors such as the clinical effectiveness in real world settings, the drugs’ added clinical benefit over the standard available therapy at market entry, as well as pricing, accessibility, and affordability of the therapy. Our methodology described below draws from 22 different international metrics, which we refer to as evaluation metrics, that reveal some aspect of added clinical benefit of a drug over existing treatments. We also take patient population size and cost-effectiveness (to the extent that it is included in health technology assessment scores) into account but construct a weighting routine that reflects some of the key aspects of added clinical benefit for AM, non-AM comparator, and oncology drugs, employing a multicriteria decision analysis approach.

### 5.1.1 Evaluation Metrics

To assess a given drug’s comparative added clinical benefit within each cohort, we collected different types of information that are likely to correlate with some aspect of added clinical benefit. We treated the information collected as metrics, where data were available, to garner a more comprehensive view of added clinical benefit and to rank the drugs by their relative added clinical benefit within each cohort. Some of the evaluation metrics we compiled were only applicable to AM drugs and hence were not used in the assessments for the non-AM comparator and oncology drug cohorts. We describe each evaluation metric used in our assessment in detail in the following sections.

#### 5.1.1.1 Select Drug Characteristics

We compiled information on whether the drug was a New Molecular Entity (NME), a New Chemical Entity (NCE) and what the drug’s route of administration (i.e., intravenous, oral) is for all drugs across the three cohorts. This information was largely gathered from the drug profiles on Drugs@FDA.

Additionally, we estimated the market size for each drug in the non-AM comparator and oncology cohorts using two metrics: the approximate number of annual cases for the drug’s indication as well as an estimate of the number of other drugs for that indication on the market. If a drug was approved for more than one indication, we added the approximate number of annual cases for each indication together. We only used the original indication(s) for approval. Similarly, we gathered information from Medscape’s Diseases and Medication inventory on how many drugs were approved for a certain indication and added the number of drugs together if a drug was approved for more than one indication.

For the AM cohort, we used Carr & Stringer’s (2019) estimates for estimated inpatient treatment courses for each infection from their 2019 Antibiotic and Antifungal Update, instead of the number of annual cases, along with the number of other drugs on the market for that indication as measure of approximate market size and anticipated patient population. For AM drugs, we also compiled information about the drug’s expected activity against CDC urgent pathogens, WHO critical threat pathogens, and ESKAPE pathogens (Enterococcus faecium, Staphylococcus aureus, Klebsiella pneumoniae, Acinetobacter baumannii, Pseudomonas aeruginosa, and Enterobacter species).

#### 5.1.1.2 European Health Technology Assessments

Countries around the world have devised systems and organized bodies that regulate drug and other therapeutics’ quality and efficacy. Many of them are part of the International Network of Agencies for Health Technology Assessment (INAHTA), which defines an HTA as “a multidisciplinary process that uses explicit methods to determine the value of a health technology at different points in its lifecycle,” the purpose of which “is to inform decision-making in order to promote an equitable, efficient, and high-quality health system” (The International Network of Agencies for Health Technology Assessment, 2020a).

We reviewed the health technology assessments conducted from France, the United Kingdom, and Germany. Such assessments were available for some but not all of the drugs included in this analysis.

##### France

The Haute Autorité de Santé (HAS) based out of Paris, France is a consulting body whose goal is to evaluate health products from a medical and economic viewpoint. HAS releases assessments that rate the actual clinical benefit (ACB) as well as the clinical added value (CAV) of medicinal products. The ACB rates the benefit of a drug based on its clinical efficacy and the condition treated by levels: substantial, moderate, low, or insufficient. The CAV rates the benefit in comparison with existing treatments, ranking the improvement in treatment on a scale from I (major) to IV (minor), with V indicating “no clinical added value” (Haute Autorité de santé, 2019; The International Network of Agencies for Health Technology Assessment, 2020b).

##### United Kingdom

The National Institute for Health and Care Excellence (NICE) out of Manchester, United Kington is a public body responsible for providing national guidance on various health products. NICE carries out HTAs and publishes corresponding guidance for the public and health professionals for prescribing certain drugs. Both clinical efficacy as well as acquisition cost data are considered in the summarized evidence and recommendations (The International Network of Agencies for Health Technology Assessment, 2020c).

##### Germany

The Institute for Quality and Efficiency in Health Care (IQWiG), out of Cologne, Germany, is a private foundation which conducts and publishes assessments on the quality and efficiency of health services. One product IQWiG provides is dossier assessments, in which IQWiG assesses dossiers submitted by manufacturers to determine whether new drugs at market entry provide any additional benefit to the standard therapy. The added benefit is classified as considerable, minor, non-quantifiable, or not proven (IQWiG, n.d.; The International Network of Agencies for Health Technology Assessment, 2020d).

#### 5.1.1.3 Institute for Clinical and Economic Review Value Assessments

The Institute for Clinical and Economic Review (ICER) is an organization that assesses the clinical and economic value of prescription drugs and other health technologies. ICER conducts value assessments based on clinical data and input from stakeholders such as patients, doctors, private insurers, and the government. A drug’s value takes into consideration both the long- term value for money and the short-term affordability. ICER considers long-term value for money the primary consideration for clinical value and determines this based on comparative clinical effectiveness, incremental cost-effectiveness, as well as other benefits and disadvantages to the drug. ICER determines the secondary consideration, short-term affordability, through looking at the potential budget impact for health care providers that would arise from introducing this new drug (Institute for Clinical and Economic Review, 2020). ICER ranks comparative clinical effectiveness based on the net health benefit of the new therapy as well as the level of certainty of the assessment. The evidence rating matrix ICER uses is depicted in Figure 6.

ICER conducts assessments for specific therapeutic areas, and accordingly rates the therapies in that area; for example, the broader CAR-T therapies assessment included a specific assessment of the FDA-approved drug axicabtagene ciloleucel or Yescarta™. In this assessment, ICER also issued an Affordability and Access Alert, which is another value rating tool that makes note of whether “added health care costs may be difficult for the system to absorb over the short term” (Institute for Clinical and Economic Review, 2018). ICER clinical value assessments were only available for drugs in our oncology cohort.

#### 5.1.1.4 Trinity Drug Index

In 2016, Trinity began publishing comprehensive evaluations of FDA approved drugs. Trinity has published Drug Indices in 2016, 2017, 2018, and 2019, rating novel drugs that were approved in 2013, 2014, 2015, and 2016, respectively. Trinity reviews each drug and assigns a score in three categories: commercial performance, therapeutic value, and research and development (R&D) complexity. Each drug also receives an overall composite score based on the three categories on a scale from 1 to 5 (Fitzhenry, et al., 2016).

The commercial performance score rates how well the drug has performed and how it is predicted to perform in the future. These are determined based on cumulative sales to date and projected sales. The therapeutic score rates the drug’s novelty, if it filled an unmet need, and how the drug compared to the standard of care when it was released. Trinity determines the additional value provided by the drug through surveys of life sciences experts and practicing physicians. The R&D score rates how long the clinical development took and how many patients participated in the trials in comparison with the cost of the process. Finally, the overall score combines the commercial (40 percent), therapeutic (40 percent), and R&D (20 percent) scores for a composite look at each novel drug. Across all four publications, only a subset of drugs in our sample were included in Trinity’s assessments.

Figure 6 ICER’s Evidence Rating Matrix

A = “Superior” – High certainty of a substantial (moderate-large) net health benefit

B = “Incremental” – High certainty of a small net health benefit

C = “Comparable”- High certainty of a comparable net health benefit

D= “Negative”- High certainty of an inferior net health benefit

B+= “Incremental or Better” – Moderate certainty of a small or substantial net health benefit, with high certainty of at least a small net health benefit

C+ = “Comparable or Incremental” – Moderate certainty of a comparable or small net health benefit, with high certainty of at least a comparable net health benefit

C- = “Comparable or Inferior” – Moderate certainty that the net health benefit is either comparable or inferior, with high certainty of at best a comparable net health benefit

C++ = “Comparable or Better” – Moderate certainty of a comparable, small, or substantial net health benefit, with high certainty of at least a comparable net health benefit

P/I = “Promising but Inconclusive” – Moderate certainty of a small or substantial net health benefit, small likelihood of a negative net health benefit

I = “Insufficient” – Any situation in which the level of certainty in the evidence is low

The picture depicts ICER’s evidence rating matrix. It plots level of certainty in the analysis against comparative net health benfit.

Source: Institute for Clinical and Economic Review (2022)

#### 5.1.1.5 Inclusion in Guidelines and Recommendations

We reviewed available guidelines and recommendation documents from the Infectious Diseases Society of America (IDSA) and Pharmacy & Therapeutics (P&T) Community to see if a given drug in our sample is included in their recommendations.

##### Infectious Diseases Society of America (IDSA) Guidelines

The Infectious Diseases Society of America (IDSA) is an organization made up of physicians, scientists, and public health experts who specialize in infectious diseases and promote infectious disease research and patient care. As part of improving infectious disease care, IDSA publishes practice guidelines for both patients and physicians. These guidelines review clinical evidence as well as extensive data from literature and provide treatment guidelines for specific therapeutic areas or clinical circumstances such as guidelines for skin and soft tissue infections or for outpatient parenteral antimicrobial therapy. The guidelines provide recommendations for a range of clinical situations from diagnosis to treatment (Infectious Diseases Society of America, 2020).

We reviewed the IDSA guidelines if they included one of our selected drugs in their therapy recommendations. As these guidelines are only for infectious disease therapies, the recommendations only included select drugs from the AM and non-AM comparator cohorts.

##### Pharmacy & Therapeutics (P&T) Community Decisions

The Pharmacy & Therapeutics (P&T) Community and their online journal, P&T® Journal provide key information on new drugs and therapies for pharmacy and therapeutics committee members. Experts in the field author articles in this journal so that P&T committees may make more informed formulary and medication-related policy decisions. For each drug that P&T® covers, experts describe the indications and usage, pharmacology, clinical trials, dosage, specific warnings and precautions, and the cost of the therapy. Taking all of these sections into considerations, P&T® then offers a conclusion on the drug’s recommended place in therapy i.e., a first-line option or a last-line choice.

#### 5.1.1.6 Medicaid Coverage

We compiled information from the Medicaid formularies for the ten states with the largest Medicaid markets: California, New York, Texas, Pennsylvania, Florida, Ohio, Illinois, Massachusetts, Michigan, and New Jersey using the searchable medical reference for clinicians, Epocrates® that allows querying each state’s Medicaid formulary for specific drugs.^26^ With narrow exceptions, Medicaid is required to cover all FDA-approved medications from manufacturers participating in the Medicaid Drug Rebate Program. For each drug, the formulary indicates the level of coverage for a drug under Medicaid in that state. Different levels of coverage include Y: Covered – No Prior Authorization Required, PPA: Preferred – Prior Authorization Required, PA: Prior Authorization Required, NPA: Non-Preferred – Prior Authorization Required, and N: Not Covered.^27^ However, each state has slightly different reimbursement methodologies for determining at what level a drug is covered which reflects the state-specific ingredient costs and pharmacy dispensing fees. Thus, the category ‘N’ appears to align with ‘NPA’ in that these products are not preferred, but prescribers would need to go through different processes to access products in the ‘N’ category versus in the ‘NPA’ category. Products may also be designated ‘N’ because the state has not yet made a coverage determination (that is, the P&T Committee has not met yet to develop coverage criteria), or because the manufacturer has not hit the mandatory effective date for state coverage yet. The ‘N’ category may also indicate that the company may not have a rebate agreement in place yet. Nonetheless, we judged that a drug having a covered or preferred prior authorization status in a state’s Medicaid program is an indicator of drug accessibility. Hence, we counted how many states out of ten either covered or denoted ‘preferred prior authorization’ for each drug as an assessment of drug accessibility.

#### 5.1.1.7 Automated Antimicrobial Susceptibility Test (AST) Device Incorporation

Antimicrobial Susceptibility Tests (ASTs) are testing methods used in hospitals and laboratories to determine whether a certain microorganism is susceptible or resistant to an AM drug. Automated AST systems test panels of tens of drugs at a time against a sample. However, AST device companies must first decide which drugs to incorporate onto the test panels for each system. We conducted a series of interviews with stakeholders in the AST industry and heard from an expert at one such automated AST device company that these companies tend to carry out thorough vetting analyses when deciding whether to incorporate a newly FDA-approved AM drug into their systems. This analysis factors in efficacy, resistance patterns and unmet need, customer demand, as well as predicted economic success. There also are additional considerations, e.g., the physical properties of certain AM compounds that may preclude their inclusion in these devices.

We compiled data on whether a given drug in the AM cohort was incorporated onto the two leading AST devices, bioMérieux’s Vitek® 2 and Beckman Coulter’s MicroScan, that together comprise roughly 90 percent of the device market.^28^ Since these two large AST manufacturers control the market, they can decide which AM drugs get incorporated onto their devices and when with little competition. We assumed that incorporation on to one or both of these devices indicates the automated AST device companies’ internal evaluations of the added clinical benefit as well as the anticipated market demand for the new AM drug.

#### 5.1.1.8 FDA Qualified Infectious Disease Product (QIDP) Classification

According to the GAIN Act provisions, under section 505E of the 34 Federal Food, Drug, and Cosmetic Act (FD&C Act) (21 U.S.C. 355f), development of antibacterial and antifungal drugs for human use to treat serious or life-threatening infections is incentivized in several ways. First, those drug products that have been designated as a Qualified Infectious Disease Product (QIDP) and approved under section 505 of the FD&C Act are granted a 5-year exclusivity extension which is added to any exclusivity the application qualifies for upon approval. Additionally, FDA gives priority review to the first application submitted for approval for a QIDP. The application can also receive fast track designation if requested by the application sponsor (U.S. Food and Drug Administration, 2018). All of the drugs in the AM cohort, except for Teflaro and Vibativ that were approved prior to the passage of the GAIN Act, had received QIDP designations from FDA.

#### 5.1.1.9 Receipt of Funding from HHS Biomedical Advanced Research and Development Authority (BARDA)

The Biomedical Advanced Research and Development Authority (BARDA) is part of the Department of Health and Human Services (HHS) Office of the Assistant Secretary for Preparedness and Response (ASPR) and was established in part to protect the country from emerging infectious diseases as well as chemical and biological threats. BARDA therefore supports specific drugs, vaccines, and diagnostics that contribute to their mission. In particular, one of BARDA’s goals is to incentivize antibacterial research and development in order to reduce antimicrobial resistant bacterial infections that may follow a public health emergency. BARDA has subsequently provided funding to several AM drugs to support preclinical and clinical development through FDA approval. Thus, we recorded which drugs in the AM cohort received funding from BARDA as another metric of added clinical benefit.

### 5.1.2 Evaluating Comparative Added Clinical Benefit

Based on the information available for each metric, we ranked each drug with 1 being the highest rank compared to the others in the cohort. The Trinity Drug Index, for example, assigned scores on a scale from 1 to 5 for five out of the twelve drugs in the AM cohort. We ranked the drug with the highest score “1,” the second highest “2,” and so on. We did this using MS Excel’s rank function for all of the drugs in the cohort. However, many metrics did not have quantitative scoring or numerical data available. For those metrics, we qualitatively assigned rankings based on context and best professional judgment. For example, the French HTAs rated a drug’s actual clinical benefit from “substantial” to “insufficient.” For these, we ranked “substantial” as the highest and assigned rankings sequentially based on the assessment ratings.

We determined that each metric likely did not reveal added clinical benefit to the same extent. For example, ten out of twelve AM drugs received QIDP designation. While an important metric in identifying drugs that will treat serious or life-threatening infections, QIDP designation will not be able to effectively differentiate the relative added clinical benefit of each drug within the AM cohort. For this reason, we devised a weighting system that would place metrics in “added clinical benefit categories” that would allow us to synthesize the data on more equal footings (see Table 15). We also wanted the categories to be applicable to all three cohorts of drugs to allow for parallel comparative added clinical benefit analyses.

Based on input from HHS, we classified several metrics as key, i.e., that would be most revealing of a drug’s added clinical benefit. For all three cohorts, we treated the Trinity Drug Index and other countries’ assessments (HAS, NICE, IQWiG) as key indicators of the added clinical benefit of those drugs assessed. Here we treated the Trinity Drug Index as one metric and only incorporated the overall score. Another key metric for all cohorts was the drug’s route of administration. We ranked all drugs with oral formulations higher than those with intravenous or other formulations to reflect the value created by allowing for outpatient prescriptions. For oncology drugs, we also included ICER’s assessment as a key metric. While not applicable to the non-AM comparator and oncology cohorts, we also designated activity against CDC/WHO pathogens as well as automated AST device incorporation as key metrics for AM drugs.

For each cohort, we first sorted all of the metrics into different added clinical benefit categories. Next, we averaged the rank score of metrics comprising an added clinical benefit category for each drug. For example, under the Market Performance added clinical benefit category, if drug X had a rank score of 1 for the automated AST device incorporation metric and a 3 for the Trinity Drug Index commercial score metric, then we calculated the Market Performance added clinical benefit category score for drug X as 2 (= [1+3] / 2). This is equivalent to a weighting routine that assigns a weight of 0.5 to the automated AST device incorporation and the Trinity Drug Index commercial score metrics.

We repeated this process five times for each cohort, such that the metrics were sorted into different combinations of added clinical benefit categories each time, i.e., added clinical benefit category sets 1 through 5 (Table 15), and no single added clinical benefit category has a disproportionate influence on the overall comparative added clinical benefit assessment. The intent of the iteration was to minimize any impact from the manner in which these metrics were grouped on the overall ranking of each drug. For example, if a given drug consistently receives a lower rank score across the different added clinical benefit category divisions, then this increases the degree of confidence in the robustness of the relative ranking of that drug generated by this approach. For each set of added clinical benefit category set 1 through 5, we then computed the aggregate added clinical benefit score for each drug, which is the simple sum of the calculated added clinical benefit category set scores.^29^

Table 15 Added Clinical Benefit Category Sets Used in Analysis

Added Clinical Benefit Category Set | Added Clinical Benefit Category | Metric
Set 1 - All Metrics (Unweighted) | All Metrics Unweighted | New Molecular Entity
Set 1 - All Metrics (Unweighted) | All Metrics Unweighted | New Chemical Entity
Set 1 - All Metrics (Unweighted) | All Metrics Unweighted | Route of Administration
Set 1 - All Metrics (Unweighted) | All Metrics Unweighted | Annual Number of U.S. Cases (non-AM & oncology)
Set 1 - All Metrics (Unweighted) | All Metrics Unweighted | Estimated Market Size (AM)
Set 1 - All Metrics (Unweighted) | All Metrics Unweighted | Number of Drugs for Indication
Set 1 - All Metrics (Unweighted) | All Metrics Unweighted | Activity against ESKAPE Pathogens (AM)
Set 1 - All Metrics (Unweighted) | All Metrics Unweighted | Activity against CDC urgent WHO critical pathogens (AM)
Set 1 - All Metrics (Unweighted) | All Metrics Unweighted | Trinity Drug Index Therapeutic Score
Set 1 - All Metrics (Unweighted) | All Metrics Unweighted | Trinity Drug Index Commercial Score
Set 1 - All Metrics (Unweighted) | All Metrics Unweighted | Trinity Drug Index R&D Score
Set 1 - All Metrics (Unweighted) | All Metrics Unweighted | HAS ACB
Set 1 - All Metrics (Unweighted) | All Metrics Unweighted | HAS CAV
Set 1 - All Metrics (Unweighted) | All Metrics Unweighted | NICE
Set 1 - All Metrics (Unweighted) | All Metrics Unweighted | IQWiG
Set 1 - All Metrics (Unweighted) | All Metrics Unweighted | AST Device Incorporation (AM)
Set 1 - All Metrics (Unweighted) | All Metrics Unweighted | QDIP Designation (AM)
Set 1 - All Metrics (Unweighted) | All Metrics Unweighted | BARDA Funding (AM)
Set 1 - All Metrics (Unweighted) | All Metrics Unweighted | P&T Community Decision
Set 1 - All Metrics (Unweighted) | All Metrics Unweighted | IDSA Guideline Inclusion
Set 1 - All Metrics (Unweighted) | All Metrics Unweighted | ICER Assessment
Set 1 - All Metrics (Unweighted) | All Metrics Unweighted | Medicaid Coverage
Set 2 - Most Revealing Metrics (Key Metrics) | Most Revealing Metrics (Key Metrics) | Activity against CDC urgent WHO critical pathogens (AM)
Set 2 - Most Revealing Metrics (Key Metrics) | Most Revealing Metrics (Key Metrics) | Trinity Drug Index Overall Score
Set 2 - Most Revealing Metrics (Key Metrics) | Most Revealing Metrics (Key Metrics) | HAS ACB
Set 2 - Most Revealing Metrics (Key Metrics) | Most Revealing Metrics (Key Metrics) | HAS CAV
Set 2 - Most Revealing Metrics (Key Metrics) | Most Revealing Metrics (Key Metrics) | NICE
Set 2 - Most Revealing Metrics (Key Metrics) | Most Revealing Metrics (Key Metrics) | IQWiG
Set 2 - Most Revealing Metrics (Key Metrics) | Most Revealing Metrics (Key Metrics) | AST Device Incorporation (AM)
Set 2 - Most Revealing Metrics (Key Metrics) | Most Revealing Metrics (Key Metrics) | ICER Assessment
Set 3 - Non-key, European HTA, Trinity Drug Index, Accessibility, and AM Key Metrics Combination | Non-Key Metrics | Annual Number of U.S. Cases (non-AM & oncology)
Set 3 - Non-key, European HTA, Trinity Drug Index, Accessibility, and AM Key Metrics Combination | Non-Key Metrics | Number of Drugs for Indication
Set 3 - Non-key, European HTA, Trinity Drug Index, Accessibility, and AM Key Metrics Combination | Non-Key Metrics | Estimated Market Size (AM)
Set 3 - Non-key, European HTA, Trinity Drug Index, Accessibility, and AM Key Metrics Combination | Non-Key Metrics | New Molecular Entity
Set 3 - Non-key, European HTA, Trinity Drug Index, Accessibility, and AM Key Metrics Combination | Non-Key Metrics | New Chemical Entity
Set 3 - Non-key, European HTA, Trinity Drug Index, Accessibility, and AM Key Metrics Combination | Non-Key Metrics | Activity against ESKAPE Pathogens (AM)
Set 3 - Non-key, European HTA, Trinity Drug Index, Accessibility, and AM Key Metrics Combination | Non-Key Metrics | QDIP Designation (AM)
Set 3 - Non-key, European HTA, Trinity Drug Index, Accessibility, and AM Key Metrics Combination | Non-Key Metrics | IDSA Guideline Inclusion
Set 3 - Non-key, European HTA, Trinity Drug Index, Accessibility, and AM Key Metrics Combination | Non-Key Metrics | BARDA Funding (AM)
Set 3 - Non-key, European HTA, Trinity Drug Index, Accessibility, and AM Key Metrics Combination | Non-Key Metrics | Medicaid Coverage
Set 3 - Non-key, European HTA, Trinity Drug Index, Accessibility, and AM Key Metrics Combination | Non-Key Metrics | P&T Community Decision
Set 3 - Non-key, European HTA, Trinity Drug Index, Accessibility, and AM Key Metrics Combination | European HTA | HAS ACB
Set 3 - Non-key, European HTA, Trinity Drug Index, Accessibility, and AM Key Metrics Combination | European HTA | HAS CAV
Set 3 - Non-key, European HTA, Trinity Drug Index, Accessibility, and AM Key Metrics Combination | European HTA | NICE
Set 3 - Non-key, European HTA, Trinity Drug Index, Accessibility, and AM Key Metrics Combination | European HTA | IQWiG
Set 3 - Non-key, European HTA, Trinity Drug Index, Accessibility, and AM Key Metrics Combination | Trinity Drug Index | Trinity Drug Index Overall Score
Set 3 - Non-key, European HTA, Trinity Drug Index, Accessibility, and AM Key Metrics Combination | Accessibility | ICER Assessment
Set 3 - Non-key, European HTA, Trinity Drug Index, Accessibility, and AM Key Metrics Combination | Accessibility | Route of Administration
Set 3 - Non-key, European HTA, Trinity Drug Index, Accessibility, and AM Key Metrics Combination | AM Key Metrics | AST Device Incorporations (AM)
Set 3 - Non-key, European HTA, Trinity Drug Index, Accessibility, and AM Key Metrics Combination | AM Key Metrics | Activity against CDC urgent WHO critical pathogens (AM)
Set 4 - Market Size, Unmet Need/Novelty, AM Drug Activity, Cost, European HTA, Market Performance, and Guideline/Recommendation Inclusion Metrics Combination | Market Size | Annual Number of U.S. Cases (non-AM & oncology)
Set 4 - Market Size, Unmet Need/Novelty, AM Drug Activity, Cost, European HTA, Market Performance, and Guideline/Recommendation Inclusion Metrics Combination | Market Size | Number of Drugs for Indication
Set 4 - Market Size, Unmet Need/Novelty, AM Drug Activity, Cost, European HTA, Market Performance, and Guideline/Recommendation Inclusion Metrics Combination | Market Size | Estimated Market Size (AM)
Set 4 - Market Size, Unmet Need/Novelty, AM Drug Activity, Cost, European HTA, Market Performance, and Guideline/Recommendation Inclusion Metrics Combination | Unmet Need/Novelty | New Molecular Entity
Set 4 - Market Size, Unmet Need/Novelty, AM Drug Activity, Cost, European HTA, Market Performance, and Guideline/Recommendation Inclusion Metrics Combination | Unmet Need/Novelty | New Chemical Entity
Set 4 - Market Size, Unmet Need/Novelty, AM Drug Activity, Cost, European HTA, Market Performance, and Guideline/Recommendation Inclusion Metrics Combination | Unmet Need/Novelty | Trinity Drug Index Therapeutic Score
Set 4 - Market Size, Unmet Need/Novelty, AM Drug Activity, Cost, European HTA, Market Performance, and Guideline/Recommendation Inclusion Metrics Combination | Unmet Need/Novelty | Route of Administration
Set 4 - Market Size, Unmet Need/Novelty, AM Drug Activity, Cost, European HTA, Market Performance, and Guideline/Recommendation Inclusion Metrics Combination | AM Drug Activity | QDIP Designation (AM)
Set 4 - Market Size, Unmet Need/Novelty, AM Drug Activity, Cost, European HTA, Market Performance, and Guideline/Recommendation Inclusion Metrics Combination | AM Drug Activity | Activity against ESKAPE Pathogens (AM)
Set 4 - Market Size, Unmet Need/Novelty, AM Drug Activity, Cost, European HTA, Market Performance, and Guideline/Recommendation Inclusion Metrics Combination | AM Drug Activity | Activity against CDC urgent WHO critical pathogens (AM)
Set 4 - Market Size, Unmet Need/Novelty, AM Drug Activity, Cost, European HTA, Market Performance, and Guideline/Recommendation Inclusion Metrics Combination | AM Drug Activity | BARDA Funding (AM)
Set 4 - Market Size, Unmet Need/Novelty, AM Drug Activity, Cost, European HTA, Market Performance, and Guideline/Recommendation Inclusion Metrics Combination | Cost | Medicaid Coverage
Set 4 - Market Size, Unmet Need/Novelty, AM Drug Activity, Cost, European HTA, Market Performance, and Guideline/Recommendation Inclusion Metrics Combination | Cost | Trinity Drug Index R&D Score
Set 4 - Market Size, Unmet Need/Novelty, AM Drug Activity, Cost, European HTA, Market Performance, and Guideline/Recommendation Inclusion Metrics Combination | Cost | ICER Assessment
Set 4 - Market Size, Unmet Need/Novelty, AM Drug Activity, Cost, European HTA, Market Performance, and Guideline/Recommendation Inclusion Metrics Combination | European HTA | HAS ACB
Set 4 - Market Size, Unmet Need/Novelty, AM Drug Activity, Cost, European HTA, Market Performance, and Guideline/Recommendation Inclusion Metrics Combination | European HTA | HAS CAV
Set 4 - Market Size, Unmet Need/Novelty, AM Drug Activity, Cost, European HTA, Market Performance, and Guideline/Recommendation Inclusion Metrics Combination | European HTA | NICE
Set 4 - Market Size, Unmet Need/Novelty, AM Drug Activity, Cost, European HTA, Market Performance, and Guideline/Recommendation Inclusion Metrics Combination | European HTA | IQWiG
Set 4 - Market Size, Unmet Need/Novelty, AM Drug Activity, Cost, European HTA, Market Performance, and Guideline/Recommendation Inclusion Metrics Combination | Market Performance | AST Device Incorporation (AM)
Set 4 - Market Size, Unmet Need/Novelty, AM Drug Activity, Cost, European HTA, Market Performance, and Guideline/Recommendation Inclusion Metrics Combination | Market Performance | Trinity Drug Index Commercial Score
Set 4 - Market Size, Unmet Need/Novelty, AM Drug Activity, Cost, European HTA, Market Performance, and Guideline/Recommendation Inclusion Metrics Combination | Inclusion in Recommendations | IDSA Guideline Inclusion
Set 4 - Market Size, Unmet Need/Novelty, AM Drug Activity, Cost, European HTA, Market Performance, and Guideline/Recommendation Inclusion Metrics Combination | Inclusion in Recommendations | P&T Community Decision
Set 5 - Market Value, Pre-approval Assessment, Added Value to Therapy, Clinical Efficacy, Accessibility, and Post-approval Use Metrics Combination | Market Value | Trinity Drug Index Commercial Score
Set 5 - Market Value, Pre-approval Assessment, Added Value to Therapy, Clinical Efficacy, Accessibility, and Post-approval Use Metrics Combination | Market Value | Estimated Market Size (AM)
Set 5 - Market Value, Pre-approval Assessment, Added Value to Therapy, Clinical Efficacy, Accessibility, and Post-approval Use Metrics Combination | Market Value | Annual Number of U.S. Cases (non-AM & oncology)
Set 5 - Market Value, Pre-approval Assessment, Added Value to Therapy, Clinical Efficacy, Accessibility, and Post-approval Use Metrics Combination | Market Value | Number of Drugs for Indication
Set 5 - Market Value, Pre-approval Assessment, Added Value to Therapy, Clinical Efficacy, Accessibility, and Post-approval Use Metrics Combination | Pre-approval Assessment | Trinity Drug Index R&D Score
Set 5 - Market Value, Pre-approval Assessment, Added Value to Therapy, Clinical Efficacy, Accessibility, and Post-approval Use Metrics Combination | Pre-approval Assessment | BARDA Funding (AM)
Set 5 - Market Value, Pre-approval Assessment, Added Value to Therapy, Clinical Efficacy, Accessibility, and Post-approval Use Metrics Combination | Pre-approval Assessment | New Molecular Entity
Set 5 - Market Value, Pre-approval Assessment, Added Value to Therapy, Clinical Efficacy, Accessibility, and Post-approval Use Metrics Combination | Pre-approval Assessment | New Chemical Entity
Set 5 - Market Value, Pre-approval Assessment, Added Value to Therapy, Clinical Efficacy, Accessibility, and Post-approval Use Metrics Combination | Pre-approval Assessment | QDIP Designation (AM)
Set 5 - Market Value, Pre-approval Assessment, Added Value to Therapy, Clinical Efficacy, Accessibility, and Post-approval Use Metrics Combination | Added Value to Therapy | Trinity Drug Index Therapeutic Score
Set 5 - Market Value, Pre-approval Assessment, Added Value to Therapy, Clinical Efficacy, Accessibility, and Post-approval Use Metrics Combination | Added Value to Therapy | HAS CAV
Set 5 - Market Value, Pre-approval Assessment, Added Value to Therapy, Clinical Efficacy, Accessibility, and Post-approval Use Metrics Combination | Added Value to Therapy | ICER Assessment
Set 5 - Market Value, Pre-approval Assessment, Added Value to Therapy, Clinical Efficacy, Accessibility, and Post-approval Use Metrics Combination | Added Value to Therapy | IQWiG
Set 5 - Market Value, Pre-approval Assessment, Added Value to Therapy, Clinical Efficacy, Accessibility, and Post-approval Use Metrics Combination | Clinical Efficacy | NICE
Set 5 - Market Value, Pre-approval Assessment, Added Value to Therapy, Clinical Efficacy, Accessibility, and Post-approval Use Metrics Combination | Clinical Efficacy | HAS ACB
Set 5 - Market Value, Pre-approval Assessment, Added Value to Therapy, Clinical Efficacy, Accessibility, and Post-approval Use Metrics Combination | Accessibility | Medicaid Coverage
Set 5 - Market Value, Pre-approval Assessment, Added Value to Therapy, Clinical Efficacy, Accessibility, and Post-approval Use Metrics Combination | Accessibility | AST Device Incorporation (AM)
Set 5 - Market Value, Pre-approval Assessment, Added Value to Therapy, Clinical Efficacy, Accessibility, and Post-approval Use Metrics Combination | Accessibility | Route of Administration
Set 5 - Market Value, Pre-approval Assessment, Added Value to Therapy, Clinical Efficacy, Accessibility, and Post-approval Use Metrics Combination | Post-approval Use | IDSA Guideline Inclusion
Set 5 - Market Value, Pre-approval Assessment, Added Value to Therapy, Clinical Efficacy, Accessibility, and Post-approval Use Metrics Combination | Post-approval Use | P&T Community Decision
Set 5 - Market Value, Pre-approval Assessment, Added Value to Therapy, Clinical Efficacy, Accessibility, and Post-approval Use Metrics Combination | Post-approval Use | Activity against ESKAPE Pathogens (AM)
Set 5 - Market Value, Pre-approval Assessment, Added Value to Therapy, Clinical Efficacy, Accessibility, and Post-approval Use Metrics Combination | Post-approval Use | Activity against CDC urgent WHO critical pathogens (AM)

Finally, summing the five aggregate scores, we arrived at an overall score for each drug that allowed us to rank order the drugs in each cohort. This sum is not intended to be a quantitative measure of added clinical benefit, rather a way to reveal which drugs were often ranked high, as represented by smaller sums, and which were ranked low, as represented by larger sums. Table 16 presents this analysis for the AM cohort.

Using the overall score for each drug, we categorized the drugs in each cohort as high added clinical benefit, intermediate added clinical benefit, or indeterminate added clinical benefit. For the drugs with the least number of available metrics, we determined that there was insufficient data for a reliable added clinical benefit assessment. Therefore, we categorized these drugs with insufficient data as having an indeterminate added clinical benefit. For the drugs with more metrics available, those with the highest overall scores were placed in the high added clinical benefit group, and others were placed in the intermediate added clinical benefit group. The analysis implicitly uses the availability of a particular metric as a measure of added clinical benefit in and of itself. In other words, if a drug has an HTA, has been incorporated into an automated AST device, assigned a Trinity Drug Index score, etc., it must have a higher added clinical benefit than one that lacks these types of assessments. However, lack of these assessments may not necessarily be due to lower added clinical value if the drug has not been on the market for an extended period to allow for the assessments to be performed.

Table 16 Evaluation of Comparative Added Clinical Benefit - Detailed Results for the AM Drug Cohort

Added Clinical Benefit Category Set 1 | | Added Clinical Benefit Category Set 2 | | Added Clinical Benefit Category Set 3 | | Added Clinical Benefit Category Set 4 | | Added Clinical Benefit Category Set 5 | | Sum Across All Category Sets
Trade Name | Aggregate Score 1 [a] | Trade Name | Aggregate Score 2 [a] | Trade Name | Aggregate Score 3 [a] | Trade Name | Aggregate Score 4 [a] | Trade Name | Aggregate Score 5 [a] | Trade Name | Overall Score [a] | Number of Metrics Available
Zerbaxa | 55 | Vabomere | 15 | Sivextro | 22 | Zerbaxa | 13 | Zerbaxa | 17 | Zerbaxa | 123 | 31
Sivextro | 58 | Zerbaxa | 15 | Zerbaxa | 23 | Avycaz | 14 | Avycaz | 19 | Avycaz | 135 | 33
Avycaz | 62 | Avycaz | 16 | Orbactiv | 23 | Sivextro | 16 | Sivextro | 19 | Vabomere | 142 | 28
Orbactiv | 63 | Sivextro | 31 | Avycaz | 24 | Vabomere | 16 | Vabomere | 20 | Sivextro | 146 | 28
Vabomere | 65 | Dalvance | 33 | Dalvance | 25 | Orbactiv | 20 | Orbactiv | 21 | Orbactiv | 162 | 28
Dalvance | 66 | Xerava | 33 | Vabomere | 26 | Baxdela | 20 | Dalvance | 21 | Dalvance | 165 | 28
Baxdela | 80 | Teflaro | 34 | Teflaro | 32 | Dalvance | 20 | Baxdela | 28 | Baxdela | 194 | 21
Nuzyra | 82 | Baxdela | 34 | Baxdela | 32 | Nuzyra | 21 | Teflaro | 28 | Nuzyra | 203 | 21
Xerava | 87 | Orbactiv | 35 | Nuzyra | 34 | Xerava | 23 | Nuzyra | 29 | Xerava | 209 | 25
Teflaro | 92 | Nuzyra | 37 | Xerava | 36 | Teflaro | 23 | Xerava | 31 | Teflaro | 210 | 23
Zemdri | 107 | Zemdri | 40 | Vibativ | 42 | Vibativ | 28 | Vibativ | 36 | Zemdri | 256 | 21
Vibativ | 113 | Vibativ | 45 | Zemdri | 43 | Zemdri | 29 | Zemdri | 37 | Vibativ | 264 | 22

[a] Lower scores indicate higher rank.

### 5.1.3 Sensitivity Analysis Involving European HTAs

Drug industry experts noted that only drugs that explicitly apply for approval in Europe are included on European HTAs (HAS, NICE, and IQWiG above). Additionally, small U.S. drug makers must have partners to sponsor marketing in Europe, meaning that it is possible for a drug to gain approval in Europe but not have any marketing or sales on the continent. Since the developers of those drugs that were not included on HTAs either did not apply for European approval or the drugs have not been on the market long enough for inclusion, we repeated the full clinical effectiveness assessment, excluding the European HTA-related metrics to gauge the robustness of our clinical effectiveness divisions as well as the sensitivity of our overall results to this metric. We then compared the relative drug rankings of the original analysis to the results of the sensitivity analysis. This sensitivity analysis is presented in the following section.

## 5.2 RESULTS

The three added clinical benefit groups, i.e., high, intermediate, and indeterminate, reveal overall comparative added clinical benefit but are not intended for a quantitative ranking of drugs within each group. The comparative added clinical benefit of the drugs in the three cohorts based on this methodology is presented in Table 17 along with the results from the sensitivity analysis discussed in Section 5.1.3. Our discussions with federal experts and individuals with prescribing experience largely corroborate these results.

While the year of approval was not part of the ranking process, it is nonetheless an important factor to consider in interpreting these results. From Table 16 and Table 17, we can see that all 3 AM drugs approved in 2018 did not have enough available information for reliable results, placing them in the indeterminate category. More recently approved drugs may not have had enough time on the market to be considered in guidance or HTAs, meaning the methodology may tend to favor AM drugs that were approved earlier and thus have more data available. We note however, that this problem did not appear as prevalent in the non-AM comparator and oncology cohorts, where drugs from 2018 were placed in the high value division in either the baseline or sensitivity analysis.

Even though only a select number of drugs may have applied for approval in Europe, our sensitivity analysis produced comparable results to the baseline analysis. Without the European clinical assessment data, the majority of drugs remained in the same comparative added clinical benefit group, with only a few moving from intermediate to high or vice versa. The stability of the ranking for drugs such as Zerbaxa and Avycaz, Veltassa and Lokelma, and Rubraca and Ibrance that are at the top in both analyses for the three cohorts, respectively, suggests that the methodology is fairly robust to changing underlying metrics and/or how metrics are grouped to form added clinical benefit category sets.

Many of the metrics used in this assessment, such as European HTAs and the Trinity Drug Index Therapeutic score, are designed to assess the added clinical benefit of a drug using information either at or a few years after market approval. In cases where antimicrobial stewardship and limited numbers of difficult-to-treat infections may make Phase 3 superiority trials difficult or not possible, the developed methodology integrates readily available public information to provide a quick, transparent, and consistent means of assessing comparative added clinical benefit.

## 5.3 LIMITATIONS

The methodology has several limitations. First, due to insufficient public health metric data for more recently approved drugs, the results may skew towards rating older drugs higher because the methodology implicitly treats the availability of a particular metric as a measure of added clinical benefit in and of itself. However, the absence of one or more metrics for a given drug may not necessarily be due to lower added clinical benefit of that drug if the drug has not been on the market long enough. There may also be other reasons, e.g., the physical properties of an AM compound may not allow it to be incorporated into automated AST devices. Second, the five added clinical benefit category sets were created using professional judgement and expert opinion but are not exhaustive of ways to categorize these metrics.

Table 17 Comparative Added Clinical Benefit Groups for AM, non-AM Comparator, and Oncology Drugs

Drug Cohort | Added Clinical Benefit Group | Baseline Assessment | | Sensitivity Analysis
Drug Cohort | Added Clinical Benefit Group | Trade Name | Approval Year | Drug Name | Approval Year
AM | High | Zerbaxa | 2014 | Avycaz | 2015
AM | High | Avycaz | 2015 | Zerbaxa | 2014
AM | High | Vabomere | 2017 | Sivextro | 2014
AM | High | Sivextro | 2014 | Orbactiv | 2014
AM | Intermediate | Orbactiv | 2014 | Dalvance | 2014
AM | Intermediate | Dalvance | 2014 | Vabomere | 2017
AM | Intermediate | Teflaro | 2010 | Teflaro | 2010
AM | Indeterminate | Baxdela | 2017 | Baxdela | 2017
AM | Indeterminate | Xerava | 2018 | Xerava | 2018
AM | Indeterminate | Nuzyra | 2018 | Nuzyra | 2018
AM | Indeterminate | Zemdri | 2018 | Zemdri | 2018
AM | Indeterminate | Vibativ | 2009 | Vibativ | 2009
Non-AM | High | Veltassa | 2015 | Veltassa | 2015
Non-AM | High | Lokelma | 2018 | Lokelma | 2018
Non-AM | Intermediate | Bridion | 2015 | Bridion | 2015
Non-AM | Intermediate | Giapreza | 2017 | Giapreza | 2017
Non-AM | Indeterminate | Surfaxin | 2012 | Surfaxin | 2012
Non-AM | Indeterminate | Vistogard | 2015 | Vistogard | 2015
Oncology | High | Rubraca | 2016 | Ibrance | 2012
Oncology | High | Zelboraf | 2011 | Rubraca | 2016
Oncology | High | Ibrance | 2012 | Erivedge | 2012
Oncology | High | Erivedge | 2012 | Braftovi | 2018
Oncology | Intermediate | Stivarga | 2012 | Zelboraf | 2011
Oncology | Intermediate | Darzalex | 2015 | Stivarga | 2012
Oncology | Intermediate | Jevtana | 2010 | Cyramza | 2014
Oncology | Intermediate | Braftovi | 2018 | Darzalex | 2015
Oncology | Intermediate | Yondelis | 2015 | Yondelis | 2015
Oncology | Intermediate | Portrazza | 2015 | Jevtana | 2010
Oncology | Intermediate | Yescarta | 2017 | Portrazza | 2015
Oncology | Intermediate | Cyramza | 2014 | Yescarta | 2017
Oncology | Indeterminate | Cometriq | 2012 | Cometriq | 2012
Oncology | Indeterminate | Vitrakvi | 2018 | Vitrakvi | 2018

25 We elected to not search for ‘Clinical Trial’ or ‘Randomized Controlled Trial’ articles to avoid literature on clinical efficacy studies conducted during clinical research.

26 A similar analysis was not feasible for Medicare coverage because Medicare Part A, B, D formularies are not publicly available.

27 A ‘Not Covered’ designation indicates that a drug is not on the state’s Medicaid formulary. An individual may request an exemption if a drug is not on the Medicaid formulary.

28 BD Phoenix™, commands less than 5 percent of the market with the remaining market share spread over those systems manufactured by smaller companies.

29 Note that in one case we only factored the metrics we found most revealing, or ‘key’ metrics, into the aggregate score.