# 4 DEVELOPMENT AND APPROVAL COST ANALYSIS

Development of AM drugs is often cited as expensive and difficult (Rex, et al., 2014; White, A.R. on behalf of the BSAC Working Party on The Urgent Need: Regenerating, 2011; Piddocck, 2012). Towse, et al. (2017) estimated the expected capitalized cost of developing an AM drug targeted against MDR pathogens that would be used exclusively within an acute care setting at $1.9 billion^14^ which accounts for the cost of failures and cost of capital. This figure is comparable to the cost of drug development across all therapeutic areas at $1.8 billion but less than half the cost of developing oncology drugs (i.e., antineoplastic and immunomodulating agents) at $4.5 billion reported in Wouters, et al. (2020). Towse, et al. (2017) also found that the development costs would be offset by nearly 60 percent (from $1.9 billion down to $0.8 billion) with matched funding as part of a public-private partnership for R&D combined with the implementation of Tier B framework for registration (Rex, et al., 2014) which would rely on a single Phase 3 study supplemented with small comparative/descriptive studies. The study reported Phase 1, 2, and 3 out-of pocket costs of $19.4 million, $71.5 million, and $237.4 million, respectively along with $48.4 million in post-launch study costs, which appear to be based solely on expert judgment.^15^ In a more recent study, Wouters, et al. (2020) estimated the cash outlay needed to develop an anti-infective agent for systemic use at $0.4 billion (95% CI: $0.3 – 0.5 billion) and the expected capitalized development and approval costs that account for failures and cost of capital at $1.3 billion (95% CI: $0.7 - $1.9 billion). These costs were based on a sample of five AM drugs approved during 2009–2018 and included Xerava (eravacycline), Orbactiv (oritavancin), Dificid (fidaxomicin), Nuzyra (omadacycline), and Zerbaxa (ceftolozane + tazobactam), of which four are also in the AM drug cohort. Table 6 presents the costs Wouters, et al. (2020) reported for these drugs by phase.

Table 6 Development and Approval Cost [a] Estimates for Select AM Drugs from Wouters, et al. (2020)

Trade Name | Preclinical | Phase 1 | Phase 2 | Phase 3 | Total | Quality of Estimate
Dificid | $26.3 | $4.2 | $6.9 | $128.7 | $166.1 | Medium
Nuzyra | NA | $205.9 | NA | $255.9 | $461.8 | Medium [b]
Orbactiv | NA | NA | NA | $155.9 | $155.9 | Medium
Xerava | NA | $31.0 | $31.6 | $325.3 | $387.9 | High [c]
Zerbaxa | NA | NA | $279.3 | $628.4 | $907.7 | Low
Average | $26.3 | $80.4 | $105.9 | $298.8 | $415.9

Source: Wouters, et al. (2020)

NA = Not available (The authors noted that they were unable to disaggregate expenditures among phases for some drugs and hence did not record costs in those cases.)

[a] Represents the cash outlay unadjusted for failures or cost capital.

[b] Authors reported using the accumulated deficit of $197.9 million as of December 2014 as a proxy for early development since the company appeared to focus solely on Nuzyra.

[c] The figures counted funding extended by the U.S. government from HHS Biomedical Advanced Research and Development Authority (BARDA) and the National Institute of Allergy and Infectious Disease (NIAID) at the Natiional Institutes of Health (NIH).

In two independent surveys of pharmaceutical companies involved in AM development, 80 and 84 percent of survey respondents indicated that economic barriers, high costs, and low return on investment, were the main reasons for suspending AM clinical trial development (The Review on Antimicrobial Resistance, 2015; Bettiol & Harbarth, 2015). Complexity, scientific risk and “unreasonably long recruitment period” were also cited as further development barriers (Bettiol & Harbarth, 2015). Enrollment for clinical trials can also be difficult for AM drugs that target resistant infections, which have short treatment courses requiring immediate treatment, and have small patient populations (Duke Margolis Center for Health Policy, 2019). In particular, studies noted that Phase 3 trials are often so complex and costly that smaller companies and start-ups in the development space are unable to develop new agents (Piddocck, 2012).

In a series of interviews ERG (2018) conducted with AM drug venture capital investors and early-stage drug developers, one expert broke down the cost of developing a novel AM drug into preclinical research ($2 million); staff, researcher and CRO funding ($125 million); facilities, and equipment funding ($125 million); and the three phases of the clinical development (Phase 1 at $12 million, Phase 2 at $7.5 million, and Phase 3 at $35 to $40 million). The expert estimated that these activities combined could cost over $300 million. Other drug developer interviewees in this group agreed that these novel AM drugs rarely have revenues greater than $50 million per year, which makes it difficult to achieve profitability on a timeline acceptable to private investors and before market protections expire.

Given the wide range of published development cost estimates and the judgement-based nature of the underlying development stage-specific cost figures that appear to have been used in generating those estimates, we wanted to use a transparent bottom-up model to estimate development costs for each of the drugs in our cohorts. Figure 3 below depicts a stylized model of the drug development process from conception through post marketing activities that we used as the basis of our development cost analysis (Eastern Research Group, Inc., 2020).

From Figure 3, the initial phase of development begins with the exploratory stage which includes identification and validation of a “druggable” target for a specific disease (A—Target Discovery).^16^ Once a target candidate is identified and validated, the developer uses screening approaches to identify a “hit” compound (i.e., a compound that interacts with the target of interest) using such strategies as high-throughput screening, phenotypic screening, virtual screening, fragment-based screening and structure-based design (B—Hit Generation) (Lansdowne, 2020). Next, the developer works on refining these “hits” to optimize their pharmacokinetic properties while also investigating their “off-target” interactions to get a sense of potential adverse effects (C—Lead Identification). After optimizing the lead compound (D—Lead Optimization), preclinical in-vitro and in-vivo testing (E—Preclinical Animal Models) is conducted to begin accumulating evidence of the compound’s biological affect (U.S. Food and Drug Administration, 2018). The developer then uses animal models to answer such questions as “What does the drug do to the body?,” “What does the body do to the drug?,” and “It is potent, but is it safe?” (Lansdowne, 2020).

Upon completion of early discovery and preclinical testing (Stages A through E in Figure 3), the developer must submit an investigational new drug (IND) application to the FDA before clinical testing on human subjects may begin (F—FDA IND Submission). The IND application includes “…animal study data and toxicity (side effects that cause great harm) data; manufacturing information; clinical protocols (study plans) for studies to be conducted; data from any prior human research; and information about the investigator.” (U.S. Food and Drug Administration, 2018). If the FDA reviews the IND and its proposed clinical study design and the IND becomes in effect, the sponsor may begin testing on humans under the specified IND number.

Figure 3 Stylized Model of Drug Development

Note: Pink boxes indicate steps relevant to the development of AM drugs but not to other types of drugs.

[a] Even though the manual AST device development occurs in this timeframe, the devices are not FDA cleared until after the drug has received FDA approval.

The figure shows the drug development process steps from target discovery to FDA IND submission, clinical stage (Phase 1 through 3), FDA NDA/BLA review, market launch, and post-marketing activities. The figure highlights the steps that are unique to antimicrobial drug development including manual AST development, automated AST device development, and resistance surveillance.

Once the IND is in effect, the sponsor may then begin the next phase in development, the clinical stage (Stages G, H, and J in Figure 3), which usually consists of three clinical phases. Most Phase 1 clinical studies test for safety and dosing among a small group (20 to 100) of closely monitored subjects who are either healthy or have the disease or condition.^17^ Phase 2 studies enroll several hundred subjects and provide additional information on safety and dosing as well as early evidence of efficacy and adverse events. Most Phase 3 studies enroll 300 to 3,000 or more subjects with the disease or condition and provide a thorough assessment of safety and efficacy of the drug (U.S. Food and Drug Administration, 2018). As expected, patient enrollment by clinical phase for the drugs across our three cohorts are broadly in line with these reported ranges (Table 7).

To support approval, drug efficacy is usually demonstrated througtableh well-controlled randomized and double-blind trials. These trials can be designed to show superiority or noninferiority to a comparator. The goal of a superiority trial is to demonstrate that a new drug is better than an active comparator or placebo whereas a noninferiority trial aims to demonstrate that a new drug is not clinically inferior to an active comparator or placebo. (Christensen, 2007; Head, et al., 2012; U.S. Food and Drug Administration, 2016). Typically, patient enrollment needs for superiority trials tend to be larger than those for noninferiority and equivalence trials given the need to demonstrate a statistically significant improvement over an active comparator or placebo. If a new drug is the same general type as a drug already on the market, the sponsor must conduct a noninferiority study at a minimum (U.S. Food and Drug Administration, 2016). All drugs in the AM cohort have done noninferiority Phase 3 trials whereas most of the drugs in the non-AM comparator and oncology cohorts have done superiority trials. There are several factors that make superiority Phase 3 trials—which often require higher number of patients than those for noninferiority trials—for AM drugs infeasible. It is difficult to recruit patients with a specific pathogen infection quickly especially without appropriate rapid diagnostics. Further, serious infections can progress rapidly before an informed consent can be obtained from the patient and before the patient’s culture results are available (National Academies of Sciences, Engineering, and Medicine, 2022).

Table 7 Average Number of Patients Enrolled, by Phase and Drug Cohort

Phase | AM Cohort Drugs | Non-AM Comparator Cohort Drugs | Oncology Cohort Drugs
Clinical
Phase 1 | 270 (156 – 507) | 155 (27 – 367) | 145 (8 – 454)
Phase 2 | 237 (88 – 430) | 244 (2 – 770) | 396 (97 – 1,613)
Phase 3 | 1,948 (627 – 3,532) | 1,031 (243 – 1,886) | 2,257 (330 – 5,054)
Clinical Total | 2,413 (889 – 4,046) | 1,430 (562 – 2,416) | 2,314 (119 – 6,763)
Post-approval
Phase 4 | 1,293 (12 – 7,923) | 2,193 (20 – 8,615) | 462 (65 – 1,623)
Overall Total | 3,706 (1,399 – 10,916) | 3,623 (622 – 11,031) | 2,777 (581 – 7,225)

Note: The numbers in parentheses represent the minimum and maximum.

Phases 2 and 3 are also when AM drug manufacturers begin working with one or more device manufacturers to facilitate the development of manual Antimicrobial Susceptibility Tests (AST) using the dosage and efficacy data generated (I—Manual AST Device Development). These tests allow users to test a sample of a microorganism against a selection of AM drugs and identify whether that sample is susceptible (S), intermediate (I), or resistant (R) to the AM drugs at the given dosage. Clearance these testing devices by the FDA for marketing are also critical for appropriate drug prescribing in hospital settings and therefore market uptake. Additional manual AST devices are also developed after market approval of the AM drug. However, those device manufacturers that are able to use the clinical data generated during the AM drug’s Phase 2 and 3 clinical trials to support their 510(k) application to FDA for their manual AST devices often receive clearance either at, or soon after, drug approval.

Upon completion of clinical trials to support approval, the developer then submits to the FDA a New Drug Application (NDA) if the drug is a pharmaceutical or a Biologics License Application (BLA)) if the drug is a biologic.^18^ The application must demonstrate safety and efficacy, as well as an acceptable manufacturing process, which is confirmed through a manufacturing facility inspection. Once the appropriate center conducts a scientific review, the applicable FDA product advisory committee may be asked to opine on the benefit-to-risk ratio of the drug. The center considers the advisory committee comments (if applicable) before approval, which allows the developer to bring the drug to the market. Once on the market, the drug enters the post-marketing stage, which may include conducting Phase 4 studies to investigate rare cases or special populations and to monitor adverse events; studying the safety and efficacy of the drug on pediatric populations; and submitting batch manufacturing samples to FDA for potency, safety, and purity tests. For AM drugs, post-approval commitments often include these Phase 4 studies, but may also require additional Phase 3 efficacy studies, such as neonatal sepsis studies for gram-positive drugs^19^ or additional pneumonia studies. Additionally, automated AST device development commences at this stage as well (M—Automated AST Device Development). Most laboratories often elect to use automated AST devices, which require less labor and test more AM drugs at a time than their manual counterparts. These automated devices run tests in anywhere from 5 to 24 hours depending on the machine and the replication time of the pathogen. Thus, getting on an automated AST device is important for gaining widespread use for AM drug manufacturers but may take several years to accomplish after approval or may not happen at all. The AM drug manufacturers have little or no control over getting their drugs incorporated into these devices or its timing (see Section 5.1.1.7 for further discussion). Even when a drug is approved and its AST method has received a 510(k) clearance from FDA for incorporation into an automated AST device, it may still take significant time for the automated AST device manufacturer to incorporate the drug into its device and make it available for laboratory use.^20^ AM drug manufacturers also must complete 5 years of compulsory surveillance of resistance trends (N—Automated Surveillance) (Krause, 2019).

Apart from the development stages depicted in Figure 3, there are additional activities for which the developer expends resources for, such as chemistry, manufacturing, and controls (CMC) and manufacturing plant design/build. However, cost data on these activities are scarce. Because the magnitude of resources spent on these activities are not expected to vary significantly from one type of drug to the next, we did not account for these in our stylized model.

Based on Figure 3, we estimated the cost of developing a drug by considering the cost, duration, the probability of successfully transitioning from one stage to the next, and the opportunity cost of capital using the approach developed by DiMasi, et al. (2016). For the purpose of this analysis, we broke down the overall development of a drug as shown in Figure 3, into six distinct stages, including 1—non-clinical, which includes all steps in between target discovery (Phase A) and FDA IND approval (Phase F), 2—Phase 1, 3—Phase 2, 4—Phase 3, 5—FDA review, and 6—Phase 4. If the cash outlay (aka development and approval cost) associated with a given phase i is C_i_, then the expected cost, E(C), that incorporates failures can be computed by dividing this cost by the transition success probability from phase i to launch, p_i_, i.e.,

E (C_i_) = (C_i_)/(p_i_) (1)

Assuming that phase costs are distributed uniformly over the length of the phase, t_i_, the capitalized cost, CC, that accounts for the opportunity cost of the investment in the drug, i.e., the rate of return (net of inflation) that the sponsor would otherwise be able to earn at the same risk level as the investment in the new drug that has been selected (see Section 4.2.9), is given by:

C C_i_ = ∫_t_i_^e^_^t_i_^b^^ ((C_i_)/(t_i_)) e^r t^ d t (2)

where r is the opportunity cost of capital that captures the time value effect; t_i_^b^ is the time from the beginning, b, of the given phase to product launch, and t_i_^e^ is the time from the end, e, of the given phase to product launch. Equation 2 then becomes:

C C_i_ = ((C_i_ / t_i_))/(r) (e^r t_i_^b^^ - e^r t_i_^e^^) (3)

Given equations 1 and 3, we can then compute the expected capitalized cost of phase i that accounts for the cost of failures as well as the opportunity cost of capital as:

E (C C_i_) = (C C_i_)/(p_i_) (4)

Then the total expected capitalized cost of development for a drug, E(CC), is the sum of the expected capitalized cost of each phase i,

E ( C C ) = ∑_i = 1_^n^ E (C C_i_) (5)

where i = non-clinical, Phase 1, Phase 2, Phase 3, FDA BLA/NDA review, and Phase 4 for drugs.

The following sections describe the data sources utilized in operationalizing the above framework and the specific model parameters and assumptions.

## 4.1 DATA SOURCES

We describe the primary data sources used in the modeling in the following sections. In addition to these data sources, we also used published studies to support our parameter estimates and assumptions. We note these in the applicable sections. As noted above, all data collected on each drug are presented in Appendix A.

### 4.1.1 Clinicaltrials.gov Data

Clinicaltrials.gov is a registry launched in September 2008 to provide protocol and results information on clinical trials conducted in the U.S. and around the world. Clinicaltrials.gov data are updated daily and provide information on such parameters as study start and end dates and number of patients enrolled for the registered studies that are relevant for our analysis. We used a snapshot of the clinicaltrials.gov data downloaded on June 24, 2020 through the Clinical Trials Transformation Initiative’s (CTTI) Access to Aggregate Content of ClinicalTrials.gov (AACT) initiative.

Using SAS, we queried the AACT database for all clinical trials relevant to each drug selected. We then restricted our sample to only include trials that were not terminated or withdrawn and were interventional in nature, where the intervention was a drug or a biological. Further, we only kept Phase 1, 2, and 3 trials that began before the BLA/NDA submission date because we wanted to capture those trials that were supportive of the BLA/NDA or were Phase 4 post-approval studies. Table 8 summarizes the relevant attributes taken from the AACT database as well as any criteria that would determine whether a particular trial was in scope for the analysis. This query resulted in a total of 400 Phase 1 through 4 trials for the selected drugs across all three drug cohorts. This likely is an underestimate of the number of trials conducted for any given compound as early phase trials are often not registered in clinicaltrials.gov.

Table 8 Clinical Trial Attributes Recorded from the AACT Database and Drugs@FDA

Clinical Trial Attribute | In-scope Criteria
Trial Type | Interventional
Intervention Type | Drug or Biological
NCT ID | NA
Phase | Phases 1 and 2 must have a: start date < NDA submission date [a] AND completion date < NDA approval date*; Phase 3 must have a: start date < NDA submission date*; Phase 4 must have a: start date > NDA submission*
Start Date | NA
End Date (Primary Completion Date if Available) | NA
Trial Status | Status must not be ‘Terminated’ or ‘Withdrawn’
Region Trial Took Place | NA
Enrollment | NA

NA = Not applicable

[a] Information obtained from Drugs@FDA.

### 4.1.2 Drugs@FDA and FDA Orange Book: Approved Drug Products with Therapeutic Equivalence Evaluations

Drugs@FDA and FDA Orange Book are online publicly available resources containing applicable information on current FDA-approved drugs. Drugs@FDA is an online database that includes patient information, label, application reviews, and other documentation including any BLA/NDA approval documents for most CBER/CDER approved drug products since 1939. FDA publication Approved Drug Products with Therapeutic Equivalence Evaluations (commonly known as the Orange Book) contains patent and exclusivity information on drug products approved by FDA under the Federal Food, Drug, and Cosmetic Act. The Orange Book also has an online database searchable by both drug and patent information.

Since Phase 1 trials are not required to be registered in Clinicaltrials.gov and other recording inconsistencies are known to be present within the database, we supplemented the automated query of the AACT database with a manual search of each drug’s BLA/NDA available through the Drugs@FDA database for any additional trials. We applied the same criteria listed in Table 8 above to these trials. We also recorded the drug investigational new drug (IND) application date, the BLA/NDA submission date, and the BLA/NDA approval date from this database. Finally, we queried the Orange Book database for all drugs in the cohort and recorded the United States Patent and Trademark Office (USPTO) filing date.

### 4.1.3 IQVIA GrantPlan®

IQVIA’s GrantPlan is a large database of current clinical investigator budgets from 62 countries. The database contains cost data compiled from final negotiated budgets between sponsors and investigator sites at the procedure, cost per visit, and cost per patient levels from countries involved in drug testing throughout North America, Europe, Asia, and Latin America. The database includes cost information from 48 sponsors and 12 CROs that conduct 76 percent of all global clinical trials. We obtained a custom tabulation from this database that provided cost estimates by therapeutic area, phase, and country along with applicable overhead benchmarks covering the period from 2015 through 2019. These data served as the basis for estimating cost adjustment factors for clinical trials by world regions (i.e., Europe, North America, Central America, South America, Asia, Africa, Middle East, Oceania).

## 4.2 MODEL PARAMETERS AND ASSUMPTIONS

### 4.2.1 Phase Durations

The phase duration parameter refers to the time it takes to complete a given stage of development depicted in Figure 3. Using the clinical trials deemed in scope, we estimated the duration of Phase 1 – 4 trials as the total time from the start date of the earliest reported clinical trial for that phase to the end date of the latest clinical trial reported for that phase for each drug in our three cohorts. If there were no studies available for one phase of a particular drug’s development, we imputed a value based on the average duration for that phase across all drugs in that cohort.

For the non-clinical stage, our estimate represents the time it takes from synthesis of the compound to the start of human trials, which includes early exploratory research for target discovery, hit generation and target identification; lead optimization; preclinical work involving animal testing to develop dosing and toxicity models; and obtaining an IND approval from FDA to begin testing in human subjects. To encompass this, we defined the non-clinical phase duration as the time between the USPTO Registration of Compound and the FDA IND submission date for each drug.

Finally, we set the duration of the NDA review phase to be the time between NDA submission and BLA/NDA approval.

### 4.2.2 Time from Phase Start to Next Phase Start

The start-to-start parameter refers to the elapsed time between the start of one development phase (e.g., Phase 2) supporting a BLA/NDA and the start of the next development phase (e.g., Phase 3) supporting the same application. For the non-clinical phase to Phase 1 estimate, we assumed that Phase 1 will begin immediately upon successful completion of the nonclinical development phase and notification from FDA that the proposed Phase 1 study in the submitted IND may proceed, (i.e., when the IND is in effect), which is the same as the total nonclinical phase duration.

For the clinical phases 1 – 3, work may overlap. In other words, the sponsor may begin one or more Phase 2 clinical trials before completing Phase 1 clinical trials. Therefore, the start-to-start duration was total time between the start date of the earliest reported clinical trial for one phase and the start date of the earliest reported clinical trial for the subsequent phase. We did not compute the start-to-start time between Phase 3 and post approval Phase 4 studies, but instead recorded the elapsed time from the first Phase 3 trial to BLA/NDA submission, and from BLA/NDA submission to approval.

### 4.2.3 Phase Begin (Months Before Launch)

The phase begin parameter refers to the length of time from the start of each development phase to drug launch. We estimated this as the sum of all start-to-start durations between a specific phase and BLA/NDA approval (e.g., number of months Phase 2 began before launch = Phase 2 start to Phase 3 start + Phase 3 start to BLA/NDA submission + BLA/NDA submission to approval).

### 4.2.4 Phase End (Months Before Launch)

The phase end parameter refers to the length of time from the end of each development phase to drug launch. For each phase, we estimated this variable by subtracting the phase duration from each phase begin parameter (e.g., number of months Phase 2 ended before launch = number of months Phase 2 began before launch – Phase 2 duration in months).

Several drugs in our sample had Phase 3 trials that ended after BLA/NDA approval. In those cases, the Phase 3 study began before BLA/NDA submission and the manufacturer may have used preliminary results from these studies to support the BLA/NDA, but the trial was not fully completed until after drug approval. We accounted for this by splitting the Phase 3 studies into the portion leading up to approval and the portion constituting a ‘Phase 3 follow-up study.’ This is further described in our computations below.

### 4.2.5 Total Number of Patients Enrolled by Region and Phase

Number of patients enrolled in a study is the largest single factor driving study costs but the costs of conducting a study also varies by geographic region (Moore, et al., 2020). For each drug in our three cohorts, we estimated the total number of patients enrolled in supporting trials in each of the 8 regions around the world.

The trials we compiled from Clinicaltrials.gov and Drugs@FDA included the total enrollment as well as a list of countries where the various arms of the trial were conducted. The exact enrollment per country was not provided in these databases, so we mapped each country to its corresponding world region (Europe, North America, Central America, South America, Asia, Africa, Middle East, Oceania), and distributed the total trial enrollment proportionally based on the number of trial sites per region to estimate enrollment per region,^21^ i.e.:

Enrollment_region_ = (# of Sites in Region)/(Total # of Sites) × Total Enrollment (9)

If no countries were specified, we divided the enrollment evenly amongst the 8 regions. Finally, we summed the regional enrollment for each drug and each phase.

### 4.2.6 Average Cost Per Patient for Clinical Trials by Therapeutic Area and Region

The total cost of a clinical trial for a given phase and therapeutic area, C_total_, includes study-level costs (such as institutional review board approvals and source data verification costs), C_study_, patient-level costs (such as recruitment and clinical procedure costs), C_patient_, and site-level costs (such as monitoring and project management), C_site_ (Sertkaya, et al., 2016) i.e.:

C_total_ = C_study_ + C_patient_ + C_site_ (10)

Then, the average cost per-patient, CPP, can be calculated by dividing the total cost of a clinical trial C_total_, by the number of patients, n_patient_, enrolled in that trial, i.e.:

C P P = (C_total_)/(n_patient_) (11)

In a previous study, ERG (2020) used total clinical trial cost and enrolled patients data from Cutting Edge and Medidata Solutions as well as patient level costs from IQVIA to estimate average per-patient costs for biopharmaceutical clinical trials in the U.S. by therapeutic area and phase in 2018 dollars (Eastern Research Group, Inc., 2020). To be able to apply these per-patient costs to international studies, we devised scaling factors using the IQVIA per-patient costs for each geographic region and therapeutic area. To calculate the scaling factor, S, that could be used to scale U.S. per-patient trial costs to another regions, we divided the median per-patient cost for that therapeutic area and region by the median per-patient cost for that therapeutic area in North America, i.e.:

S_region , T A_ = (C P P_region , T A_)/(C P P_North America , T A_) (12)

The scaling factors were only computed by region and therapeutic area and then applied to the U.S. per-patient cost estimates by therapeutic area and phase discussed above. This yielded average cost per patient estimates for each therapeutic area, phase, and world region.

### 4.2.7 FDA User Fees

FDA is authorized to collect application fees for the review of human drug and biological products, and prescription drug program fees for certain approved products by the Federal Food, Drug, and Cosmetic Act (the FD&C Act), as amended by the Prescription Drug User Fee Amendments of 2017 (PDUFA VI). These fees change yearly in accordance with congressional reauthorization of PDUFA every five years. For this analysis, we used the rates for the 2019 fiscal year, published in 2018: $2,588,478 for an application requiring clinical data, which does not include $304,162 in associated program fees (U.S. Food and Drug Administration, 2018).

### 4.2.8 Phase Transition Success Probability

The phase transition success probability parameter represents the probability of a sponsor successfully moving from one stage of drug development depicted in Figure 3 to the next. If, for example, out of 100 new drug candidates that make it to Phase 1, 30 successfully proceed to Phase 2, then the phase transition probability from Phase 1 to Phase 2 is 30 percent.

We used figures from published studies to estimate the transition probability of success of a drug between the pre/nonclinical phase and Phase 1; Phase 1 and Phase 2; Phase 2 and Phase 3; Phase 3 and BLA/NDA submission; and BLA/NDA submission and drug approval. Table 9 shows the average probability of success between each step for the relevant therapeutic areas.

Table 9 Transition Probability of Success by Phase and Therapeutic Area

Therapeutic Area | Data Source | Time Period | Pre/Nonclinical to Phase 1 | Phase 1 to Phase 2 | Phase 2 to Phase 3 | Phase 3 to FDA BLA/NDA Submission | FDA BLA/NDA Submission to Approval
Anti-Infective | Wong et al, (2019) | 2000 – 2015 | NA | 70.1% | 58.3% | NA | NA
Anti-Infective | DiMasi et al, (2010) | 1993–2004 | NA | 58.2% | 52.2% | 78.6% | 100.0%
Anti-Infective | BiomedTracker, (2016) | 2006–2015 | NA | 69.5% | 42.7% | 72.7% | 88.7%
Anti-Infective | BiomedTracker, 2017 [a] | 2010–2016 | NA | NA | 45.0% | 71.0% | NA
Anti-Infective | Average | | 68.0% [b] | 65.9% | 49.6% | 74.1% | 94.4%
Cardiovascular | Wong et al, (2019) | 2000 – 2015 | NA | 73.3% | 65.7%
Cardiovascular | DiMasi et al, (2010) | 1993–2004 | NA | 62.9% | 32.4% | 64.3% | 66.7%
Cardiovascular | BiomedTracker, (2016) | 2006–2015 | NA | 58.9% | 24.1% | 55.5% | 84.2%
Cardiovascular | BiomedTracker, (2017) [a] | 2010–2016 | NA | NA | 26.0% | 53.0% | NA
Cardiovascular | Average | | 68.0% [b] | 65.0% | 37.1% | 57.6% | 75.5%
Genitourinary System | Wong et al, (2019) | 2000 – 2015 | NA | 68.7% | 57.1%
Genitourinary System | BiomedTracker, (2016) | 2006–2015 | NA | 57.1% | 32.7% | 71.4% | 85.7%
Genitourinary System | Average | | 68.0% [b] | 62.9% | 44.9% | 71.4% | 85.7%
Oncology | Wong et al, (2019) | 2000 – 2015 | NA | 57.6% | 32.7% | NA | NA
Oncology | DiMasi et al, (2010) | 1993–2004 | NA | 71.8% | 49.0% | 55.3% | 100.0%
Oncology | BiomedTracker, (2016) | 2006–2015 | NA | 62.8% | 24.6% | 40.1% | 82.4%
Oncology | BiomedTracker, (2016) | 2006–2015 | NA | 64.1% | 23.0% | 34.2% | 79.6%
Oncology | BiomedTracker, (2016) | 2006–2015 | NA | 61.8% | 28.7% | 52.6% | 86.4%
Oncology | BiomedTracker, (2017) [a] | 2010–2016 | NA | NA | 27.0% | 45.0% | NA
Oncology | Pharma Intelligence, Informa, (2016) [a] | 2011–2015 | NA | 59.0% | 21.0% | 38.0% | 84.0%
Oncology | Pharma Intelligence, Informa, (2016) [a] | 2011–2015 | NA | 57.0% | 20.0% | 32.0% | 83.0%
Oncology | Pharma Intelligence, Informa, (2016) [a] | 2011–2015 | NA | 64.0% | 26.0% | 54.0% | 84.0%
Oncology | Pharma Intelligence, Informa, (2016) [a] | 2011–2015 | NA | 56.0% | 18.0% | 36.0% | 77.0%
Oncology | Pharma Intelligence, Informa, (2016) [a] | 2011–2015 | NA | 61.0% | 25.0% | 40.0% | 93.0%
Oncology | Average | | 68.0% [b] | 61.5% | 26.8% | 42.7% | 85.5%
Respiratory System | DiMasi et al, (2010) | 1993–2004 | NA | 72.5% | 20.0% | 85.7% | 80.0%
Respiratory System | BiomedTracker, (2016) | 2006–2015 | NA | 67.6% | 32.5% | 71.4% | 93.8%
Respiratory System | BiomedTracker, (2016) | 2006–2015 | NA | 65.3% | 29.1% | 71.1% | 94.6%
Respiratory System | BiomedTracker, (2017) [a] | 2010–2016 | NA | NA | 28.0% | 74.0% | NA
Respiratory System | Average | | 68.0% [b] | 68.5% | 27.4% | 75.6% | 89.5%

NA = Not available/Not applicable

[a] From PAREXEL’s biopharmaceutical R&D statistical yearbook (PAREXEL International Corp., 2017).

[b] Transition probability from preclinical phase to Phase 1 trials for All Therapeutic Areas calculated from PAREXEL International Corp. (2017) as no information was available for the therapeutic area.

All AM drugs in our cohort fall under the anti-infective therapeutic area and drugs from the remaining 2 drug cohorts fall under the cardiovascular, genitourinary system, oncology, and respiratory system therapeutic areas. Across all therapeutic areas, successfully transitioning from Phase 2 to Phase 3 generally has the lowest likelihood ranging from 26.8 percent for oncology to 49.6 percent for anti-infective drugs. Anti-infective drugs also have a higher overall development success probability compared to other types of drugs, with 4.1 percent of oncology drugs and 15.5 percent of anti-infective drugs successfully making it from non-clinical development to market. We used these probabilities to determine the expected development and approval costs for each drug (Equation 2), using the appropriate probabilities for each drug’s therapeutic area.

### 4.2.9 Opportunity Cost of Capital Data

The opportunity cost of capital (OCOC) represents the rate of return (net of inflation) that the sponsor would otherwise be able to earn at the same risk level as the investment in the new drug that has been selected. The value of OCOC can vary significantly by sponsor-specific factors, such as product portfolio, venture capital funding, and size of company, as well as other exogenous factors, such as economic and regulatory climate for drug development projects.

There are numerous studies that have evaluated OCOC for both small and large firms in the biopharmaceutical market. Table 10 presents the different OCOC estimates available from the published literature for all sectors (biotechnology and pharmaceutical) and all firm sizes. These estimates were all made using the capital asset pricing model (CAPM) model. In our analysis, we used the average of these figures (11 percent) as the OCOC for drug development projects.

Table 10 Sources for Opportunity Cost of Capital Used in this Analysis

Data Source | Study Period | Sector | Firm Size | Type of Model | Opportunity Cost of Capital
DiMasi et al, (2003) | 2000 | Total | All | CAPM | 11.9%
DiMasi et al, (2016) | 2000 | Total | All | CAPM | 11.8%
DiMasi et al, (2016) | 2005 | Total | All | CAPM | 10.8%
DiMasi et al, (2016) | 2010 | Total | All | CAPM | 9.4%
Paul et al, (2010) | 2007 | Total | All | CAPM | 11.0%
Mean | | | | | 11.0%

### 4.2.10 Development and Approval Costs by Phase of Development

The development and approval cost parameter represents the cash outlay (not adjusted for failures or opportunity cost of capital) a sponsor incurs during a given drug development phase. Development and approval costs vary based on the number of patients enrolled as well as the countries where study arms take place. For this model, we estimated the development and approval costs for each drug for the following stages: preclinical/nonclinical, Phases 1 through 3, the FDA review period, and Phase 4 using the parameters discussed above. To calculate the development and approval costs, C, for Phases 1 – 3, we multiplied the total enrollment per region for each drug by the median cost per patient by region for the therapeutic area of that drug as shown C = Enrollment_region_ × CPP_region,TA_#(13) below.

C = Enrollment_region_ × C P P_region , T A_ (13)

To use the appropriate average cost per patient (CPP) figure, we matched each drug to its corresponding therapeutic area. All of the drugs in the AM cohorts were in the infectious disease therapeutic area and all of the drugs in the oncology cohort were in the oncology therapeutic area. The therapeutic areas varied by drug in the non-AM cohort as shown in Table 11.

Table 11 Therapeutic Areas of the Non-AM Cohort Drugs

Non-AM Drug | Therapeutic Area
Bridion | Pain and Anesthesia
Giapreza | Cardiovascular
Surfaxin | Respiratory System
Lokelma | Genitourinary System
Veltassa | Genitourinary System
Vistogard | Oncology

For all drugs with data on Phase 4 trials available, we applied the same method as we did for Phases 1 – 3, as summarized by equation 13 above to estimate the costs associated with Phase 4 post-approval studies. However, many drugs approved more recently, particularly in the AM and oncology cohorts, did not have any data available on Phase 4 trials. Using data from available Phase 4 trials, we estimated the average Phase 4 enrollment by region for the AM, non-AM comparator, and oncology cohorts. We then multiplied this enrollment by the CPP by region and phase to get regional average Phase 4 development and approval costs.^22^ The sum of the average development and approval costs for all 8 regions yielded the average total Phase 4 development and approval costs for the AM, non-AM comparator, and oncology cohorts. We applied this average to any drug that did not have any Phase 4 data available. For costs associated with the non-clinical phase, we used the method from DiMasi et al. (2016) that estimated that the early work before IND submission would cost approximately 45% of the total clinical phase costs.^23^ The development and approval costs for each drug and phase was then the simple sum of all 8 regional development and approval costs. We then calculated the total development and approval cost for every drug to get to market as the sum of the costs from the non-clinical phase, Phase 1, Phase 2, Phase 3 before BLA/NDA approval, the FDA BLA/NDA review period, and Phase 4. We calculated this total cost both with and without post-approval (Phase 4) costs.

## 4.3 RESULTS

From Table 12, the median development and approval costs including post-approval Phase 4 studies for AM drugs were nearly the same as the oncology cohort at $149.6 million and $149.8 million, respectively. These bottom-up estimates are significantly lower than those reported in Wouters, et al. (2020) (see Table 6) as they exclude operational expenditures—office rent, company staff salaries, utilities, etc.—as well as supply chain related activities—chemistry and manufacturing control (CMC) costs, plant build or redesign for manufacturing, etc.—which may be included in Wouters, et al. (2020). The median development and approval costs for the non-AM cohort were nearly half of the other two cohorts at $79.5 million. However, Figure 4 below shows how certain drugs with significantly higher development costs, such as Cyramza, which had very high enrollment during its clinical phase, skew the mean total development and approval costs for the oncology cohort ($195.8 million) to be higher than both the AM ($144.5 million) and the non-AM comparator cohorts ($104.2 million). The magnitude of development and approval costs were largely driven by patient enrollment in clinical studies as shown by similarly high average enrollments in AM and oncology Phase 1, 2, and 3 studies. The average number of patients enrolled for the clinical stage (i.e., Phase 1, 2, and 3 combined) for the AM cohort drugs was 2,413, which was comparable to those for the oncology cohort drugs at 2,314 (Table 7). The non-AM comparator cohort had many fewer participants on average (1,430) which is mirrored in the cohort’s low average development and approval costs. Of the three cohorts, non-AM drugs also had the longest time from target identification to market at an average of 20.2 years (ranging from 11 to 28.4 years). It took oncology drugs the shortest amount of time to reach market at 13.2 years (ranging from 6.6 to 23.8 years) and AM drugs a little over 2 years longer to reach market at an average of 15.8 years (ranging from 10.4 to 25 years).

From the perspective of total development and approval costs, Phase 3 studies with high enrollments comprised the largest portion of the development costs for drugs across the three cohorts. However, the probability of success for a drug to get from the pre/nonclinical phase to approval is only 15.5 percent for AM drugs and even lower for the non-AM comparator drugs (8.6 percent) and oncology drugs (4.1 percent). This probability increases significantly if the new drug candidate has already cleared the pre/nonclinical, Phase 1, and Phase 2 stages. For our three cohorts the probability of approval for a drug that entered Phase 3 is much higher at 69.9 percent for the AM cohort, 54.6 percent for the non-AM cohort, and 36.5 percent for the oncology cohort drugs.

The very low transition success probabilities at the pre/nonclinical phase mean that once we account for the costs of failures and opportunity cost of capital in the expected capitalized development and approval costs, the pre/nonclinical phase ends up constituting the majority of the development costs and accounted for on average, 75.8 percent (oncology cohort) to 78.7 percent (AM cohort) of the total costs including post-approval Phase 4 costs. Across the three cohorts, the pre/nonclinical phase lasted on average between 55 (oncology) and 63 (non-AM comparator) months but varied greatly for the drugs in the AM cohort with Xerava only taking about a year and a half for the pre/nonclinical activities and Dalvance taking nearly 9 years. We used the approach by Beall, et al (2019) and calculated pre/nonclinical duration as the time from patenting of the compound in the U.S. to the filing of an investigational new drug (IND) application with the FDA to begin testing in humans. The approach may underestimate the time from discovery to clinical phase if the compound is initially patented outside of the United States, e.g., patented with the European Patent Office (EPO) first and later with the U.S. Patent and Trademark Office (USPTO). Given that this phase accounts for a sizable portion of overall costs and publicly available information on expenditures and duration are scarce, we present our costs estimates with and without this phase in Figure 4 and Figure 5 below.

We see that AM drugs have average to high development and approval costs when compared to our other two cohorts. However, once we account for cost of failures and opportunity cost of capital, AM drugs have the lowest expected capitalized development and approval costs with a mean cost, including Phase 4 costs incurred post-approval, of $1,508 million in comparison to those for non-AM drugs ($3,198 million) and oncology drugs ($6,293 million) (Figure 5). This estimate is comparable to the average expected capitalized cost of development and approval of $1,297 million (95 percent CI: $673 million to $1,859 million) reported in Wouters, et al. (2020) for anti-infectives for systemic use. Additionally, when we exclude failure costs, as these are likely borne by investors with investments in multiple early-stage companies rather than the small single-compound AM drug developers, the mean capitalized development and approval costs estimated are $332 million (Table 12) which exceed those recently reported by (Gandhi & Schulman, 2021) by over 60 percent.

Table 12 Total Development and Approval Costs for the AM, Non-AM Comparator, and Oncology Cohorts

Cost Type | Phase | AM Cohort | | | Non-AM | | | Oncology
Cost Type | Phase | Mean | Std. Dev | Median | Mean | Std. Dev | Median | Mean | Std. Dev | Median
Development and Approval Costs (in $ 2018) | Non-clinical Phase | $39.8 | $21.0 | $41.3 | $20.1 | $9.4 | $18.9 | $47.0 | $49.8 | $29.9
Development and Approval Costs (in $ 2018) | Clinical Phase | $89.2 | $47.1 | $92.6 | $45.2 | $21.0 | $42.4 | $105.4 | $111.7 | $67.1
Development and Approval Costs (in $ 2018) | FDA Review Phase | $2.6 | $0.0 | $2.6 | $2.6 | $0.0 | $2.6 | $2.6 | $0.0 | $2.6
Development and Approval Costs (in $ 2018) | Post-Approval Phase | $12.9 | $17.7 | $10.6 | $36.3 | $62.9 | $12.5 | $40.9 | $57.9 | $7.7
Development and Approval Costs (in $ 2018) | Total without Post-approval | $131.6 | $68.1 | $136.4 | $67.9 | $30.4 | $63.9 | $155.0 | $161.4 | $99.6
Development and Approval Costs (in $ 2018) | Total with Post-approval | $144.5 | $70.5 | $149.6 | $104.2 | $68.6 | $79.5 | $195.8 | $174.7 | $149.8
Expected Development and Approval Costs (in $ 2018) – Accounts for cost of failures | Non-clinical Phase | $256.0 | $135.2 | $265.6 | $258.0 | $130.0 | $235.4 | $1,146.5 | $1,214.7 | $729.8
Expected Development and Approval Costs (in $ 2018) – Accounts for cost of failures | Clinical Phase | $151.5 | $73.8 | $164.0 | $148.6 | $70.0 | $162.1 | $632.8 | $573.7 | $500.9
Expected Development and Approval Costs (in $ 2018) – Accounts for cost of failures | FDA Review Phase | $23.6 | $0.0 | $23.6 | $23.6 | $0.0 | $23.6 | $23.6 | $0.0 | $23.6
Expected Development and Approval Costs (in $ 2018) – Accounts for cost of failures | Post-Approval Phase | $12.9 | $17.7 | $10.6 | $36.3 | $62.9 | $12.5 | $40.9 | $57.9 | $7.7
Expected Development and Approval Costs (in $ 2018) – Accounts for cost of failures | Total without Post-approval | $431.1 | $208.2 | $456.2 | $430.1 | $194.8 | $421.0 | $1,802.9 | $1,768.5 | $1,248.4
Expected Development and Approval Costs (in $ 2018) – Accounts for cost of failures | Total with Post-approval | $444.1 | $208.8 | $473.0 | $466.4 | $197.3 | $466.1 | $1,843.8 | $1,774.5 | $1,329.2
Capitalized Development and Approval Costs to Date of Launch (in $ 2018) – Accounts for time value of money | Non-clinical Phase | $189.2 | $112.7 | $183.9 | $168.2 | $111.1 | $137.4 | $214.8 | $300.2 | $112.6
Capitalized Development and Approval Costs to Date of Launch (in $ 2018) – Accounts for time value of money | Clinical Phase | $140.3 | $105.5 | $130.8 | $126.8 | $56.3 | $128.1 | $143.8 | $171.5 | $74.3
Capitalized Development and Approval Costs to Date of Launch (in $ 2018) – Accounts for time value of money | FDA Review Phase | $2.7 | $0.2 | $2.7 | $3.2 | $0.7 | $2.9 | $2.7 | $0.0 | $2.7
Capitalized Development and Approval Costs to Date of Launch (in $ 2018) – Accounts for time value of money | Post-Approval Phase | $8.8 | $10.6 | $8.0 | $21.0 | $31.9 | $9.4 | $14.7 | $14.6 | $5.9
Capitalized Development and Approval Costs to Date of Launch (in $ 2018) – Accounts for time value of money | Total without Post-approval | $332.3 | $206.7 | $358.5 | $298.2 | $163.8 | $269.2 | $361.3 | $458.5 | $165.3
Capitalized Development and Approval Costs to Date of Launch (in $ 2018) – Accounts for time value of money | Total with Post-approval | $341.1 | $206.8 | $362.8 | $319.2 | $155.5 | $310.7 | $376.0 | $464.8 | $181.7
Expected Capitalized Development and Approval Costs to Date of Launch (in $ 2018) – Accounts for costs of failures and opportunity cost of capital | Non-clinical Phase | $1,218.5 | $725.7 | $1,183.9 | $2,661.3 | $2,816.7 | $1,365.0 | $5,242.7 | $7,328.0 | $2,748.5
Expected Capitalized Development and Approval Costs to Date of Launch (in $ 2018) – Accounts for costs of failures and opportunity cost of capital | Clinical Phase | $255.6 | $167.9 | $249.8 | $486.7 | $398.9 | $356.6 | $1,010.8 | $1,052.8 | $718.4
Expected Capitalized Development and Approval Costs to Date of Launch (in $ 2018) – Accounts for costs of failures and opportunity cost of capital | FDA Review Phase | $25.0 | $1.7 | $24.5 | $29.4 | $6.6 | $26.4 | $24.3 | $0.3 | $24.2
Expected Capitalized Development and Approval Costs to Date of Launch (in $ 2018) – Accounts for costs of failures and opportunity cost of capital | Post-Approval Phase | $8.8 | $10.6 | $8.0 | $21.0 | $31.9 | $9.4 | $14.7 | $14.6 | $5.9
Expected Capitalized Development and Approval Costs to Date of Launch (in $ 2018) – Accounts for costs of failures and opportunity cost of capital | Total without Post-approval | $1,499.0 | $869.1 | $1,502.8 | $3,177.4 | $3,142.0 | $1,754.5 | $6,277.9 | $8,304.9 | $3,104.7
Expected Capitalized Development and Approval Costs to Date of Launch (in $ 2018) – Accounts for costs of failures and opportunity cost of capital | Total with Post-approval | $1,507.8 | $869.9 | $1,507.0 | $3,198.3 | $3,130.0 | $1,796.1 | $6,292.6 | $8,311.7 | $3,123.6

Figure 4 Development and Approval Costs with and without Pre/Nonclinical Phase Costs for AM, Non-AM Comparator, and Oncology Cohort Drugs (in 2018 $ Million)

Figure 5 Expected Capitalized Development and Approval Costs with and without Pre/Nonclinical Phase Costs for AM, Non-AM Comparator, and Oncology Cohort Drugs (in 2018 $ Million)

Note: The resulting values for Yondelis and Cyramza are due to the high number of clinical studies involving large patient populations conducted for these drugs.

## 4.4 LIMITATIONS

There are several limitations to the development cost analysis. First, the costs presented currently do not account for those expenditures related to supply chain activities; chemistry, manufacturing, and controls (CMC) processes; plant design and/or build; marketing and commercialization; or other post approval activities, such as pharmacovigilance, pediatric studies, etc. These activities have a significant burden after a drug is launched in the U.S. market (Table 13). However, with the exception of AST development ($7 million) and resistance monitoring costs ($3 - $5 million) shown in Table 13, these costs are applicable to not just AM drugs but all drugs in our non-AM comparator and oncology cohorts. Thus, they do not alter the comparative results across the three drug cohorts to any significant extent.

Table 13 Expected Five-year Expenses in $ Million for a New AM Drug for the U.S. Market Post Launch from Krause (2019)

Commitment | Single Indication, Minimum Requirements | Two Indications, Some safety Signals | Several Indications, Expected Broad Use
Pediatric Pharmacokinetic (PK) and Safety Studies | $25 | $50 | $75
Additional Phase 3 Study | NA | $50 | $75
Pharmacokinetic in Special Adult Populations | $2 | $3 | $5
Surveillance | $3 | $5 | $5
Pharmacovigilance | $5 | $5 | $5
Medical Affairs | $50 | $50 | $50
AST | $7 | $7 | $7
Drug Manufacturing | $150 | $250 | $400
Total | $242 | $420 | $622

NA = Not applicable

Second, the costs presented also do not account for the U.S. and non-U.S. government investment in these drugs that were intended to offset portions of the applicable drugs’ R&D expenses that would have been incurred by the drug developers. In that sense, they potentially overestimate the costs incurred by drug developers. For example, there are several drugs within the AM cohort (Zemdri, Vabomere, Orbactiv, Xerava, and Nuzyra) that have received sizable U.S. government grant funding for R&D according to public records available via the Federal procurement database. We estimated the U.S. grant funding received by Zemdri at $220 million, by Nuzyra at $157 million, by Xerava at $61.5 million, and by Vabomere and Orbactiv combined at $59 million,^24^ which amounts to around $498 million for the 5 AM drugs overall. While we have not been able to track U.S. government funding for the drugs in the non-AM comparator or the oncology cohorts due to company name changes resulting from mergers and acquisitions, it is possible that some of these drugs have also benefited from U.S. government funding, especially in early stages of R&D. Table 14 presents an analysis of the effects of a hypothetical $1 million in grant funding a company receives on the expected capitalized cost of drug development and approval by development phase. From the table, an early R&D grant of $1 million during pre/nonclinical development has the largest impact on mean overall development costs (−1.5 to −4.4 percent reduction) across the three cohorts. The offsetting impact of the funding on overall development costs borne by the drug developer reduces as it gets applied to later development stages.

Table 14 Change in Expected Capitalized Costs Inclusive of Post-approval Costs due to a Hypothetical $1 Million in Government Grant Funding for a Development Phase [a]

Drug Cohort | Development Phase | Change in Mean Expected Capitalized Costs Including Post-approval Costs (in 2018 $ Million) | | Change in Median Expected Capitalized Costs Including Post-approval Costs (in 2018 $ Million)
Drug Cohort | Development Phase | $ | % | $ | %
AM | Pre/Nonclinical | −$30.7 | −2.0% | −$22.0 | −1.5%
AM | Phase 1 | −$23.4 | −1.6% | −$22.6 | −1.5%
AM | Phase 2 | −$19.0 | −1.3% | −$15.9 | −1.1%
AM | Phase 3 | −$15.6 | −1.0% | −$11.7 | −0.8%
Non-AM Comparator | Pre/Nonclinical | −$141.7 | −4.4% | −$51.0 | −2.8%
Non-AM Comparator | Phase 1 | −$78.8 | −2.5% | −$27.9 | −1.6%
Non-AM Comparator | Phase 2 | −$93.8 | −2.9% | −$34.5 | −1.9%
Non-AM Comparator | Phase 3 | −$68.6 | −2.1% | −$26.3 | −1.5%
Oncology | Pre/Nonclinical | −$93.3 | −1.5% | −$124.9 | −4.0%
Oncology | Phase 1 | −$74.0 | −1.2% | −$101.2 | −3.2%
Oncology | Phase 2 | −$56.5 | −0.9% | −$72.9 | −2.3%
Oncology | Phase 3 | −$40.5 | −0.6% | −$57.9 | −1.9%

[a] To calculate the change in expected capitalized costs of a hypothetical $1 million grant funding for a given drug, we decreased the development and approval cost of a selected phase by the grant amount for each drug and re-calculated the expected capitalized costs using equations 1 through 5. We then compared this value to the expected capitalized cost previously calculated for each drug to compute the difference, The figures in the table represent the average difference across all drugs in a given cohort for that phase.

It is difficult to discern to which development stages the total U.S. government grant funding we identified for the four AM drugs would have applied. However, the amount of grant funding received for these drugs would likely have been sufficient to offset at least the sum of pre/nonclinical, Phase 1, and Phase 2 costs we estimated for Zemdri ($23 million), Nuzyra ($55 million), Xerava ($60 million) and Vabomere ($14 million) and around half of pre/nonclinical costs for Orbactiv ($55 million). This would have significantly reduced the estimated expected capitalized costs inclusive of post-approval costs incurred by the developers of those drugs. For example, a complete offset of pre/nonclinical, Phase 1, and Phase 2 costs would have reduced the expected capitalized costs inclusive of post-approval Phase 4 costs by 85 percent (from $564 to $82 million) for Zemdri, by 80 percent (from $347 to $69 million) for Vabomere, by 91 percent (from $2,111 to $199 million) for Nuzyra, by 83 percent (from $1,471 to $249 million) for Xerava, and by 39 percent (from $1,543 to $939 million) for Orbactiv.

Third, as shown in Figure 4 and Figure 5, the pre/nonclinical phase of development is a big driver of overall development costs. However, there are no publicly available estimates of pre/nonclinical costs. In modeling the expenditure associated with this stage, we used the methodology by DiMasi, et al. (2016) and assumed that the overall costs for the pre/nonclinical stage was around 45 percent of the total clinical phase (i.e., Phase 1, Phase 2, and Phase 3) costs for all drugs across the three drug cohorts. This results in allocating a sizeable amount to the pre/nonclinical stage in the modeling; $40 million for AM drugs, $20 million for non-AM comparator drugs, and $47 million for oncology drugs on average. The resulting pre/nonclinical stage cost estimates for AM drugs are, as a result, significantly higher than what we heard from an industry expert during our interviews who reported $2 million in pre/nonclinical research to find a molecule with clinical and market potential, but this is highly variable depending on the compound. Given how sensitive the overall development costs are to the expenditure associated with this stage, better information is needed to improve estimates.

Fourth, as noted above, several more recently approved drugs did not have any information on Phase 4 trials available. Therefore, we had to use an average Phase 4 cost for 5 out of the 12 AM drugs, but these costs varied greatly from $400,000 (Sivextro) to $63.6 million (Teflaro). We similarly had to apply an average Phase 4 cost to 7 out of the 14 oncology drugs, with costs ranging from $1.2 million to $19.6 million.

Finally, it was difficult to find publicly available information on early phase (Phase 1 and Phase 2) clinical trials. Some companies may have conducted these trials outside of the U.S. and thus may not have had to register them in clinical trial registries such as clinicaltrials.gov or EU Clinical Trials Register. While FDA requires companies to submit summary information on all clinical trials conducted for a compound that is the subject of an NDA, information on early phase trials were either completely or partially lacking based on our review of the statistical information packages and other publicly available information on Drugs@FDA. This would have resulted in an underestimate of R&D costs given our bottom-up methodology. Despite the missing information, however, our expected capitalized development and approval cost estimates are in line with other recently published estimates that have utilized different methodologies.

14 The reported estimate in Towse et al (2017) is $1.581 in 2011 dollars. We used U.S. Medical Care Price Index to calculate the corresponding estimate in 2018 dollars (U.S. Bureau of Labor Statistics, 2021).

15 The reported corresponding estimates in Towse et al. (2017) are $16.0 million, $59.0 million, $196.0 million, and $40.0 million in 2011 dollars, respectively. We used U.S. Medical Care Price Index to calculate the corresponding estimate in 2018 dollars (U.S. Bureau of Labor Statistics, 2021).

16 A target is deemed “druggable” if its activity can be altered by a therapeutic agent (Lansdowne, 2020).

17 For AM drugs, Phase 1 subjects are typically health volunteers.

18 Only the oncology cohort included 4 large molecule drugs (i.e., biologics) with BLAs; Portrazza (necitumumab), Yescarta (axicabtagene ciloleucel), Darzalex (daratumumab), and Cyramza (ramucirumab). The remaining drugs in the oncology cohort as well as those in the AM and non-AM comparator cohorts were small molecule drugs with NDAs.

19 Neonatal sepsis studies have been part of the pediatric post-approval commitments and can be requested for gram-negative compounds.

20 Upon receipt of 510(k) clearance from FDA, the drug’s information, including approved breakpoints, must be updated in all automated AST devices that are in operation throughout laboratories across the globe. Automated AST device manufacturers carefully plan for new drug incorporations on a 3- to 4-year cycle based on recent drug approvals and FDA 510(k) application review times. Thus, if an AM drug manufacturer misses getting onto the AST device manufacturers’ multi-year plans, they may have to wait several years before being considered again. Some automated AST devices are networked and can be updated remotely, but many are not networked. Devices that are not networked can be updated by inviting a representative from the AST device manufacturer to update the devices, or the device manufacturer may provide specific instructions to laboratory staff on how to update the devices themselves. At present, there is no protocol or timeline for when device manufacturers need to incorporate a drug following 510(k) approval, but after they incorporate a drug onto a panel, they often roll out the new panels while updating the device software. Automated AST device companies often perform these updates a few times a year and choose to bundle several newly approved drugs within each update to save costs as it is a labor-intensive and time-consuming process to visit so many laboratories.

21 It is unlikely that any given trial actually had proportionate enrollment across regions. We acknowledge that this is a simplifying assumption which may result in an over- or under-estimate of costs for those trials. However, given that only 15 percent (60 out of 400) of trials had missing trial site information in the data compiled, we expect that any error associated with assuming an equal apportionment would be relatively minor.

22 We again used the infectious disease TA CPP by region and phase for the AM cohort and the oncology TA CPP by region and phase for the oncology cohort, but since Surfaxin was the only non-AM drug that did not have Phase 4 data available, we used the respiratory TA CPP by region and phase to find the non-AM average Phase 4 development and approval costs by region.

23 Here, Phase 3 costs include costs incurred after approval.

24 The reported funding figure in FPDS-NG of around $88 million was applicable to three drugs, Vabomere, Orbactiv, and Minocin, originally developed by the Medicines Company. Since Minocin is not a part of the AM cohort, the reported $465 million overall spending likely overestimates the spending on Zemdri, Vabomere, Orbactiv, and Nuzyra by roughly $29 million assuming a third of the $88 million funding was for Minocin.