# 3 DRUGS SELECTED FOR ANALYSIS

To answer the research questions above, we selected three drug cohorts for analysis: AM drugs, comparator non-AM drugs, and oncology drugs. The AM drug cohort comprised of 12 AM drugs approved by FDA during the 2010 – 2018 period. The comparator non-AM drug cohort included 6 drugs commonly used in an inpatient setting for short durations and the oncology drug cohort had 14 oncology drugs of which 4 were large and 10 were small molecule drugs. All drugs in the comparator non-AM and oncology cohorts were approved during the 2010 – 2018 period as were the AM drugs. The sections below describe the selection criteria we used for each cohort in detail. The data compiled on each drug are provided in Appendix A.

## 3.1 AM DRUG COHORT

We expect that different segments of the AM market (e.g., oral versus intravenous AM drugs) perform differently. Thus, the AM drug cohort needed to have a balanced mix of different types of AM drugs to be representative. Table 1 presents the list of AM drugs approved by FDA for the U.S. market during the 2010 – 2018 period (20 total) along with their characteristics. Only 2 (10 percent) out of the 20 drugs are narrow spectrum; 10 (50 percent) are intravenous, 4 (20 percent) have oral and intravenous formulations, 3 (15 percent) are topical, and 3 (15 percent) are oral.

Based on discussions with the Project Advisory Group (PAG) formed for this study and other experts, we grouped the AM drugs, excluding the antifungal drug Cresemba (isavuconazonium sulfate),^10^ and the nitroimidazole drug Solosec (secnidazole) for bacterial vaginosis,^11^ depicted in Table 1 into the following five different market segments:

▪ Segment 1 – Non-systemic oral/topical AM drugs. From Table 1, there are four AM drugs that fall into this segment, including Xtoro (finafloxacin otic suspension 0.3%), Zymaxid (gatifloxacin ophthalmic solution), Aemcolo (rifamycin), and Xepi (ozenoxacin).
▪ Segment 2 – Systemic IV AM drugs with broad-spectrum activity against most gram-negative bacteria responsible for serious hospitalization-requiring infections. Relative to their generic, in-class predecessors (beta-lactam-beta-lactamase inhibitor [BL-BLI] combinations, aminoglycosides, tetracyclines), drugs in this segment have variable additional activity against a subset of bacteria expressing resistance to these older drugs (class A-D beta-lactamases, AG resistance, TCN resistance, efflux and porin mutants). This segment includes the following five AM drugs from Table 1: Zemdri (plazomicin), Avycaz (ceftazidime + avibactam), Vabomere (meropenem + vaborbactam), Zerbaxa (ceftolozane + tazobactam), and Xerava (eravacycline).
▪ Segment 3 – Systemic IV AM drugs with broad-spectrum activity against gram-positive bacteria. Drugs in this segment are long-acting glycopeptides with a similar spectrum of gram-positive activity as vancomycin. This segment includes Dalvance (dalbavancin), Orbactiv (oritavancin), and Vibativ (telavancin).
▪ Segment 4 – Systemic AM drugs often with both IV and oral formulations. Relative to their generic, in-class predecessors (tetracyclines, oxazolidinones, fluoroquinolones, beta-lactams), drugs in this segment are distinguished by their activity against MRSA, and as such, they are indicated for ABSSSI, and in some cases, CABP. While infections treated with drugs in this segment can require hospitalization, they are not of long duration. This segment includes Nuzyra (omadacycline), Sivextro (tedizolid phosphate), Baxdela (delafloxacin), and Teflaro (ceftaroline fosamil).^12^
▪ Segment 5 – AM drugs for treating Clostridioides difficile (aka C. difficile) infections. These include Dificid (fidaxomicin) and Zinplava (bezlotoxumab),^13^ a monoclonal antibody.

Table 1 AM Drugs Approved for the U.S. Market and Selected AM Drug Cohort (Denoted with [a] Next to Proprietary Name), 2010–2018

Market Segment | Trade Name | Established Name | Class | Spectrum | Gram-positive, Gram-negative or Both? | Route of Administration | Approved For
NA | Cresemba | isavuconazonium sulfate | Triazole antifungal | NA | NA | Oral & IV | Invasive aspergillosis, invasive mucormycosis
NA | Solosec | secnidazole | Nitroimidazole | Broad | Both | Oral | Bacterial vaginosis
1 | Xtoro | finafloxacin otic suspension 0.3% | Fluoroquinolone | Broad | Both | Topical | Acute otitis externa
1 | Zymaxid | gatifloxacin ophthalmic solution | Fluoroquinolone | Broad | Both | Topical | Bacterial conjunctivitis
1 | Aemcolo | rifamycin | Rifamycin | Broad | Both | Oral | Traveler’s diarrhea
1 | Xepi | ozenoxacin | Fluoroquinolone | Broad | Gram-positive | Topical | Impetigo
2 | Zemdri [a] | plazomicin | Aminoglycoside | Broad | Gram-negative | IV | CUTI
2 | Avycaz [a] | ceftazidime + avibactam | Cephalosporin/beta-lactamase inhibitor | Broad | Both | IV | CIAI, CUTI
2 | Vabomere [a] | meropenem + vaborbactam | Carbapenem/beta-lactamase inhibitor | Broad | Both | IV | CUTI
2 | Zerbaxa [a] | ceftolozane + tazobactam | Cephalosporin/beta-lactamase inhibitor | Broad | Both | IV | CIAI, CUTI
2 | Xerava [a] | eravacycline | Tetracycline | Broad | Both | IV | CIAI
3 | Dalvance [a] | dalbavancin | Glycopeptide | Broad | Gram-positive | IV | ABSSSI
3 | Orbactiv [a] | oritavancin | Glycopeptide | Broad | Gram-positive | IV | ABSSSI
3 | Vibativ [a] | telavancin | Glycopeptide | Broad | Gram-positive | IV | HABP/VABP, ABSSSI
4 | Teflaro [a] | ceftaroline fosamil | Cephalosporin | Broad | Both | IV | ABSSSI, CABP
4 | Baxdela [a] | delafloxacin | Fluoroquinolone | Broad | Both | Oral & IV | ABSSSI
4 | Sivextro [a] | tedizolid phosphate | Oxazolidinone | Broad | Gram-positive | Oral & IV | ABSSSI
4 | Nuzyra [a] | omadacycline | Tetracycline | Broad | Both | Oral & IV | CABP, ABSSSI
5 | Zinplava | bezlotoxumab | Monoclonal antibody | Narrow | Gram-positive | IV | Recurrent C. difficile infection
5 | Dificid | fidaxomicin | Macrolide | Narrow | Gram-positive | Oral | C. difficile associated diarrhea

NA = Not applicable

IV = Intravenous

CUTI = Complicated urinary tract infection

CIAI = Complicated intra-abdominal infection

ABSSSI = Acute bacterial skin and skin structure infection

HABP/VABP = Hospital-acquired bacterial pneumonia / ventilator-associated bacterial pneumonia

CABP = Community-acquired bacterial pneumonia

[a] Indicates that the drug is included in the study AM drug cohort.

We judged that the drugs in market segments 1 and 5 are not within scope of the current project. Drugs in segment 1 include oral and topical formulations that are available by prescription and self-administered by the patient. Segment 5 drugs are narrow-spectrum and are approved for treating C. difficile infections (CDIs). Even though CDI is related to antibiotic drug use, most C. difficile isolates remain susceptible to metronidazole and vancomycin, first-line treatments for CDI (Banawas, 2018; Peng, et al., 2017). After eliminating the drugs in market segments 1 and 5, the AM drug cohort included all drugs in market segments 2, 3, and 4 depicted in Table 1, i.e., Zemdri (plazomicin), Avycaz (ceftazidime + avibactam), Vabomere (meropenem + vaborbactam), Zerbaxa (ceftolozane + tazobactam), Xerava (eravacycline), Dalvance (dalbavancin), Orbactiv (oritavancin), Vibativ (telavancin), Teflaro (ceftaroline fosamil), Baxdela (delafloxacin), Sivextro (tedizolid phosphate) and Nuzyra (omadacycline).

## 3.2 NON-AM COMPARATOR DRUG COHORT

To assess if reported poor commercial market performance of AM drugs is unique, we selected a sample of non-AM drugs that are comparable to AM drugs with respect to several characteristics, which are hypothesized to be relevant for determining market success. This type of analysis is analogous to a case-control study where the AM drugs (cases) are compared to non-AM drugs (controls) that are similar in various attributes to AM drugs with respect to commercial market performance (outcome). Table 2 below outlines the attributes that characterize the AM drug cohort that we aimed to match in the non-AM comparator cohort.

Table 2 Attributes of AM Drug Case Cohort for Matching to Non-AM Comparator (Control) Cohort

Attribute | Value
Market entry time period | 2010 – 2018
Type of drug | Small molecule
Type of disease | Non-chronic
Type of FDA Submission Classification | Type 1 – New Molecular Entity
Healthcare setting | Primarily inpatient
Reimbursement | Primarily Part A DRG-based
Market competition | High

To select the non-AM comparator cohort, we looked at all new drugs approved by FDA during the 2010–2018 period (CenterWatch, 2019; U.S. Food and Drug Administration, 2018). Based on our analysis of that data, there were a total of 515 new drugs (NDAs and BLAs) approved during that period. Of these, 388 (75 percent) were small molecule drugs and the remaining 127 (25 percent) were large molecule drugs.

We then reviewed the therapeutic areas and the indications for the approved 388 small molecule drugs to identify those that are primarily used for non-chronic diseases. According to the CDC, a chronic disease is defined as a condition “that last[s] one year or more and require[s] ongoing medical attention or limits activities of daily living or both” (Centers for Disease Control and Prevention, 2019b). Chronic diseases include Alzheimer’s disease, arthritis, cancer, diabetes, epilepsy, heart disease, autoimmune diseases such as lupus and primary immune deficiency disease (PIDD), and obesity. Of the 388 drugs approved, 297 (77 percent) were for treating chronic diseases including cancer (75 out of 294 drugs, 26 percent), heart disease (27 out of 294 drugs, 9 percent), diabetes (19 out of 294, 6 percent), and HIV infection (15 out of 294 drugs, 5 percent) followed by mental illness and chronic obstructive pulmonary disease (COPD) (both 11 out of 294 drugs, 4 percent).

The remaining 91 drugs (23 percent) were typically for non-chronic conditions of varying duration. Of these drugs, however, more than half (52 out of 91, 57 percent) were for infectious diseases, with 24 (46 percent) out of the 52 anti-infective drugs being antibacterial drugs. Eliminating the 52 drugs for infectious diseases, this left a total of 39 drugs for selection into the non-AM comparator cohort (i.e., control cohort). All dermatology drugs and emergency contraception drugs that were among the remaining 39 were oral formulations for outpatient use and hence were not appropriate for inclusion in the control group, leaving a total of 15 drugs. Since all of the AM drugs selected for analysis were new molecular entities (NMEs) (i.e., the FDA submission classification was Type 1 – New Molecular Entity), we selected the drugs that were NMEs out of the remaining set, leaving us with a total of six drugs in the non-AM comparator cohort; Lokelma (sodium zirconium cyclosilicate), Valtessa (patiromer), Bridion (sugammadex), Giapreza (angiotensin II), Surfaxin (lucinactant), and Vistogard (uridine triacetate) (Table 3).

Table 3 Non-AM Comparator Cohort Candidates and Selected Non-AM Comparator Drug Cohort (Denoted with [a] Next to Proprietary Name)

Trade Name | Established Name | Route of Administration | Healthcare Setting | Approved For
Kidney Disease
Lokelma [a] | sodium zirconium cyclosilicate | Oral | Inpatient & Outpatient | For treatment of hyperkalemia
Veltassa [a] | patiromer | Oral | Inpatient & Outpatient | For treatment of hyperkalemia
Other Disease
Bridion [a] | sugammadex | IV | Inpatient | For neuromuscular blockade due to rocuronium and vecuronium during surgery
Giapreza [a] | angiotensin II | IV | Inpatient | For treatment of septic shock
Omidria | phenylephrine + ketorolac | Intraocular | Inpatient | For use in eye surgery to prevent intraoperative miosis and reduce post-operative pain
Surfaxin [a] | lucinactant | Intratracheal | Inpatient | For treatment of respiratory distress syndrome in premature infants
Vistogard [a] | uridine triacetate | Oral | Inpatient & Outpatient | For emergency treatment of patients with a fluorouracil or capecitabine overdose
Pain
Dsuvia | Sufentanil | Oral | Inpatient | For management of acute pain
Dyloject | diclofenac sodium | IV | Inpatient | For management of mild, moderate, or severe pain
Exparel | bupivacaine liposome | IV | Inpatient | For postsurgical analgesia
Oxaydo (Oxecta) | oxycodone HCl | Oral | Inpatient & Outpatient | For management of acute and chronic moderate to severe pain
Targiniq | oxycodone hydrochloride + naloxone hydrochloride | Oral | Inpatient & Outpatient | For management of severe chronic pain
Troxyca | oxycodone hydrochloride + naloxone hydrochloride | Oral | Inpatient & Outpatient | For management of severe pain
Xartemis | oxycodone hydrochloride + acetaminophen | Oral | Inpatient & Outpatient | For management of acute pain
Zohydro | hydrocodone bitartrate | Oral | Inpatient & Outpatient | For management of severe pain

[a] Indicates that the drug is in the study non-AM comparator cohort and the FDA submission classification is Type 1 – New Molecular Entity.

## 3.3 ONCOLOGY DRUG COHORT

Oncology drugs are often noted as having robust market performance. Thus, we included a cohort of oncology drugs in addition to the non-AM comparator drug cohort (Section 3.2) for analysis. Similar to the non-AM comparator cohort, we selected the oncology cohort from among those oncology drugs that were approved during the 2010 – 2018 period and were NMEs according to the FDA submission classification.

Out of the 297 small molecule new drug approvals in the U.S. during the 2010 – 2018 period, 74 (25 percent) were for cancer. Of these 74 oncology drug approvals, the majority (56 drugs, or 76 percent) were NMEs according to the type of FDA submission classification information at Drugs@FDA (U.S. Food and Drug Administration, 2019). The types of cancers these 56 drugs are indicated for include non-small cell lung cancer, metastatic breast cancer, leukemia, and lymphoma (see Table 4). Similarly, out of the 128 large molecule new drug approvals during that same time period, 34 (27 percent) were for cancer, and 30 out of 34 were original approvals.

Table 4 Breakdown of Oncology Drugs Approved in the U.S., by Cancer and Drug (Small versus Large Molecule) Type, 2010–2018

Type of Cancer | Large Molecule | | Small Molecule | | Total
Type of Cancer | Count | Percent | Count | Percent | Count | Percent
Basal Cell Carcinoma | 0 | 0.0% | 2 | 3.8% | 2 | 2.6%
Breast Cancer | 2 | 8.8% | 6 | 10.0% | 8 | 9.6%
Leukemia | 5 | 21.7% | 9 | 14.7% | 14 | 16.8%
Lung Cancer | 1 | 3.9% | 8 | 17.3% | 9 | 13.1%
Lymphoma | 3 | 8.6% | 3 | 5.1% | 6 | 6.2%
Melanoma | 1 | 5.4% | 3 | 6.0% | 4 | 5.8%
Myeloma | 2 | 2.7% | 4 | 8.0% | 6 | 6.3%
Other | 4 | 18.6% | 4 | 5.7% | 8 | 9.7%
Ovarian Cancer | 0 | 0.0% | 3 | 3.6% | 3 | 2.5%
Prostate Cancer | 1 | 2.7% | 5 | 9.8% | 6 | 7.6%
Soft Tissue Sarcoma | 1 | 3.5% | 1 | 3.0% | 2 | 3.1%
Thyroid Cancer | 0 | 0.0% | 2 | 4.3% | 2 | 3.0%
2 Types of Cancer | 5 | 13.9% | 4 | 6.3% | 9 | 8.7%
3 Types of Cancer | 3 | 3.4% | 2 | 2.4% | 5 | 2.7%
More than 3 Types of Cancer | 2 | 6.8% | | 0.0% | 2 | 2.1%
Grand Total | 30 | 100.0% | 56 | 100.0% | 86 | 100.0%

From these 86 NMEs, we wanted to select a sample 15 oncology drugs that approximately reflected the distribution of types of cancer drugs and the divide between small versus large molecule drugs represented in Table 4. To ensure that our sample was representative and adequately covered different types of cancer drugs, we randomly selected one drug per type of cancer category from all the drugs (small and large molecule) for that category. For example, out of the 9 drugs that treated lung cancer, we randomly selected only one. Although we did not discriminate between small and large molecule selections, a random sampling would tend to approximately follow the 1:2 distribution between large and small molecule drugs. This random sampling method is based on the assumption that the type of cancer is likely more influential for market performance than type of drug (small versus large molecule) and the fact that the comparison of interest is between oncology drugs as a whole and AM drugs, not between large molecule oncology drugs and AM drugs and small molecule oncology drugs and AM drugs.

The oncology drug cohort comprises the 15 drugs depicted in Table 5 and included 5 large molecule drugs, and 10 small molecule drugs, which approximately reflects the distribution of all eligible NME cancer drugs approved between 2010 and 2018. During analysis, however, we discovered that sales data were unavailable for Asparlas. Therefore, we replaced Asparlas with another drug used for the treatment of acute lymphoblastic leukemia, Erwinaze (asparaginase Erwinia chrysanthemi). However, after further analysis, we found that Erwinaze largely used previous clinical trials that were submitted as part of a biologics license application (BLA) application for ELSPAR (asparaginase). The investigational new drug (IND) request for Erwinia asparaginase was submitted in 1968 and ELSPAR later received approval in 2002, meaning the trials supporting Erwinaze’s new drug application (NDA) were much older than those of others in the oncology cohort. These factors caused Erwinaze to be a significant outlier in our development cost, clinical value, and market performance analyses. Thus, we removed Erwinaze from the analysis cohort altogether, leaving the other 14 listed drugs in Table 5 for comparison with the AM cohort.

Table 5 Oncology Drug Cohort

Cancer Category | Trade Name | Established Name | Type of Drug | Route of Administration | Approved For
Basal Cell Carcinoma | Erivedge | Vismodegib ROCHE | Small Molecule | Oral | Metastatic locally advanced basal cell carcinoma
Breast Cancer | Ibrance | Palbociclib PFIZER | Small Molecule | Oral | Metastatic breast cancer
Lung Cancer | Portrazza | Necitumumab LILLY | Large Molecule | Intra-articular, intramuscular, intravitreal | Metastatic squamous non-small cell lung cancer
Lymphoma | Yescarta | axicabtagene ciloleucel GILEAD | Large Molecule | IV | Large B-cell lymphoma
Leukemia | Asparlas [a] | calaspargase pegol-mknl SERVIER | Large Molecule | IV | Acute lymphoblastic leukemia
Leukemia | Erwinaze [a] | asparaginase Erwinia chrysanthemi JAZZ | Large Molecule | IV | Acute lymphoblastic leukemia in patients that have developed hypersensitivity to E. coli-derived asparaginase
Melanoma | Braftovi | encorafenib + Mektovi (binimetinib) PFIZER | Small Molecule | Oral | Unresectable or metastatic melanoma with a BRAF V600E or V600K mutation
Myeloma | Darzalex | Daratumumab J&J | Large Molecule | IV | Multiple myeloma
Other | Vitrakvi | Larotrectinib BAYER | Small Molecule | Oral | Solid tumors that have a neurotrophic receptor tyrosine kinase (NTRK) gene fusion and are metastatic
Ovarian Cancer | Rubraca | Rucaparib CLOVIS | Small Molecule | Oral | Ovarian, fallopian tube, or primary peritoneal cancer
Prostate Cancer | Jevtana | Cabazitaxel SANOFI | Small Molecule | IV | Metastatic castration-resistant prostate cancer
Soft Tissue Sarcoma | Yondelis | Trabectedin J&J/PHARMAMAR | Small Molecule | IV | Unresectable or metastatic liposarcoma or leiomyosarcoma
Thyroid Cancer | Cometriq | Cabozantinib EXELIXIS | Small Molecule | Oral | Progressive, metastatic medullary thyroid cancer
2 Types of Cancer | Zelboraf | Vemurafenib ROCHE | Small Molecule | Oral | Unresectable or metastatic melanoma with BRAF V600E mutation or Erdheim Chester Disease with BRAF V600 mutation
3 Types of Cancer | Stivarga | Regorafenib BAYER | Small Molecule | Oral | Metastatic colorectal cancer or unresectable or metastatic gastrointestinal stromal tumor or Hepatocellular carcinoma
More than 3 Types of Cancer | Cyramza | Ramucirumab LILLY | Large Molecule | IV | Gastric or gastro-esophageal junction adenocarcinoma, metastatic non-small cell lung cancer, metastatic colorectal cancer, hepatocellular carcinoma

IV = Intravenous

[a] Excluded from the oncology drug cohort after further analysis of clinical trial information and/ or due to unavailable sales information.

10 Anti-fungal drugs were deemed out of scope for this analysis.

11 Secnidazole was excluded from consideration because its activity against the types of pathogens associated with bacterial vaginosis is similar to metronidazole or tinidazole, the standard therapy (Petrina, et al., 2017).

12 Unlike the other drugs in this segment, Teflaro (ceftaroline fosamil) is only available in IV form.

13 Zinplava (bezlotoxumab) is a monoclonal antibody indicated to reduce recurrence of Clostridium difficile infection (CDI). It is not an antimicrobial drug but is used in conjunction with an antimicrobial drug for the treatment of CDI.