# 2 STUDY OBJECTIVES

Given the ongoing concern about poor returns on investment for AM drugs, the primary objective of this study is to compare the development costs, comparative added clinical benefit, and market performance of novel AM drugs to other types of drugs approved for the U.S. market during the 2010 – 2018 period. The comparative study will allow us to answer several questions that are of interest to policymakers, such as:

▪ What is the average development cost for a novel AM drug? How does this development cost compare to other types of drugs?
▪ What is the comparative added clinical benefit of novel AM drugs?
▪ What has been the observed market performance of novel AM drugs versus other types of drugs?
▪ How have AM drugs performed commercially relative to their comparative added clinical benefit? Is the relationship between market performance and comparative added clinical benefit for AM drugs comparable to that for other types of drugs?