# 1 INTRODUCTION

According to the Centers for Disease Control and Prevention (CDC), at least 2.8 million people in the U.S. acquire serious infections each year with bacteria that are resistant to one or more of the antimicrobial (AM) drugs designed to treat those infections. Of these, approximately 35,000 die because of drug-resistant infections (Centers for Disease Control and Prevention, 2019a). Meanwhile, the current global AM drug pipeline, comprised of 252 and 43 AM compounds in different stages of preclinical and clinical development, respectively, is not sufficiently robust to meet current and future patient demand according to some experts (The Pew Charitable Trusts, 2021a; World Health Organization, 2019). While there is no agreement on what a healthy AM pipeline looks like, many find the relatively small number of pipeline AM compounds (15 out of 43) with some potential activity for serious and life-threatening infections caused by pathogens of concern worrisome given the attrition rates in clinical trials (National Academies of Sciences, Engineering, and Medicine, 2022). Without the continued development of pipeline AM compounds and new AM compounds, expansion of resistance will continue to reduce the effectiveness of currently available AM drugs and leave many patients with few, if any, treatment options.

Despite the potential of new products to reduce the social burden associated with resistant infections, the expected returns of an AM drug on the market remain low. In the 1980s, commercializing new AM drugs was a relatively straightforward process. There were few barriers to adding new AM drugs to formularies and given the widespread use and efficacy of broad-spectrum AM drugs, developers could often rely on some degree of robust market uptake. In the 2000s, as resistance patterns emerged, some AM drugs began losing efficacy and stewardship (i.e., efforts by healthcare providers to ensure that AM drugs are used only when necessary and appropriate) increased, resulting in fewer and less frequent AM drug prescriptions (Centers for Disease Control and Prevention, 2021; Eastern Research Group, Inc., 2018).^2^ As a result, the commercial prospects for AM drugs shrank.

Antimicrobial stewardship in recent decades has been pivotal in shifting several newly-approved non-generic AM drugs to the last line of defense. Standardizing the appropriate use of drugs in healthcare facilities can reduce resistance, slow the spread of multidrug-resistant (MDR) infections, and ultimately improve patient outcomes, but also inherently causes new AM drugs to have slower market uptake than most other drugs. While reducing antimicrobial resistance (AMR), decreasing the spread of MDR infections, and improving patient outcomes are the desirable goals from a societal perspective, such measures, if successful, are further expected to reduce the number of MDR infections which will naturally contribute to slower market uptake and lower utilization of future AM drugs. There are additional factors that compound the problem of slow market uptake including the fact that AM drugs often have short treatment durations and that many new AM drugs target infections affecting small patient populations.

Based on responses in a series of interviews ERG conducted with stakeholders including infectious disease, intensive care unit, and emergency room doctors that are likely to routinely prescribe AM drugs in a hospital setting, doctors tend to be cautious and do not prescribe new AM drugs if there are older, often generic, AM drugs available as first-line treatments (Eastern Research Group, Inc., 2018). Recommended prescribing practices have also started to be implemented in the electronic health records based on how hospital administrators set their stewardship goals. These hospital administrators, including the pharmacy and therapeutics committees, must approve new medications before doctors can prescribe them, taking into consideration the clinical value of the drug, cost of the drug, and whether there are effective alternatives on the formulary. This has led to older, cheaper, broad-spectrum AM drugs being the preferred first line options. Exceptions are new AM drugs that have a shorter course of treatment or drugs that offer oral formulations, as opposed to intravenous administration, which allow the patient to be discharged more quickly.

According to some observers, the AM pipeline has also been affected by decreased investor interest and the subsequent exit of large pharmaceutical companies from the development space. A World Health Organization (WHO) study in Europe found that since 1990, the number of large pharmaceutical companies that were actively developing AM drugs has dropped from 18 to 4 and smaller companies have started to fill that space (Renwick, et al., 2016). The estimated average price tag for developing a new AM drug is between $1.3 billion (in 2018 dollars) (Wouters, et al., 2020)^3^ and $1.9 billion (in 2018 dollars) (Towse, et al., 2017)^4^ accounting for failures and cost of capital. The average yearly revenue for an AM drug, on the other hand, is $46 million according to industry analysts (Plackett, 2020). One study estimated the net present value (i.e., the sum of all development investment costs and expected present value of future revenues) for an AM drug at around $44.5 million (in $ 2018 converted from Euros) compared to $752.6 million to $1.2 billion for neurological or musculoskeletal drugs (Sciarretta, et al., 2016).^5^ Under these circumstances, the business case for investing in AM drug development is weak. However, none of these estimates account for the hundreds of millions of dollars in federal government investment in the development of these AM drugs in recent years that were intended to offset a large portion of R&D expenditures incurred by the developers. According to public records,^6^ the U.S. federal government investment alone was nearly half a billion dollars for five of the AM drugs approved during the 2014–2018 period exclusive of the value of several additional benefits, such as tax incentives and additional years of exclusivity protections.

Despite the diminished interest in developing AM drugs from investors and large pharmaceutical companies, implementation of a series of market incentives, such as grants for clinical research, product development partnerships (PDPs), tax credits, and additional years of exclusivity protections availed by the Generating Antibiotic Incentives Now (GAIN) Act of 2012, has helped to keep the AM pipeline viable, even resulting in modest gains. As can be observed from Figure 1, there has been a noticeable increase in the average number of novel AM drugs approved by FDA per year after the passage of the GAIN Act from 0.8 approvals per year during the 2002–2012 period to 1.4 approvals per year during the 2012–2021 period (GlobalData, 2018; Cunha, et al., 2019; Dheman, et al., 2021). Moreover, even though the AM drug pipeline is still viewed to be lackluster by some, the total number of AM drug candidates in the pipeline has increased by 10.5 percent from 38 to 43 (Figure 2) from 2014 to 2020 (Cunha, et al., 2019; The Pew Charitable Trusts, 2021b).

Figure 1 Novel AM Drugs Approved by FDA, 2000–2021

Source: Adapted from GlobalData (2018) and updated with data from Dheman, et al. (2021) and Cunha et al. (2019).

Figure 2 AM Drug Pipeline, by Stage of Development over Time

NDA = New Drug Application phase; Approved = Received marketing approval; Total = Sum of Phase 1, Phase 2, Phase 3, NDA, and Approved drug candidates.

Source: Adapted from Cunha et al. (2019)

During the same 2014–2020 period, FDA approved a total of 23 AM drugs, of which 20 (87 percent) had expected activity against ESKAPE pathogens, pathogens designated as urgent threats by the CDC, and/or the WHO threat pathogens.^7^ Of these 20 antimicrobial drugs, 15 received qualified infectious disease product (QIDP) designations from the FDA, which made them eligible for priority review, and were granted extended exclusivity protections.^8^ Even though the GAIN Act appears to have vitalized the AM pipeline during the 2010s, other factors likely have contributed to the increase in new AM drug approvals as well. These included changes in FDA guidance designed to streamline AM development programs and clinical trial designs followed by the establishment of the Limited Population Antibacterial Product (LPAD) pathway in 2016 (Section 3042 of Pub. L. 114–255) for certain drugs that are intended to treat serious or life-threatening infections in a limited population of patients with unmet needs (U.S. Food and Drug Administration, 2018). There also are additional incentives included in two bills under consideration in Congress, the Developing an Innovative Strategy for Antimicrobial Resistant Microorganisms (DISARM) Act and the Pioneering Antimicrobial Subscriptions to End Upsurging Resistance (PASTEUR) Act, that could further alter the AM development landscape and help bring novel AM drugs that address unmet needs to market. The DISARM Act would allow CMS to reimburse qualified AM drugs outside of the diagnosis-related group (DRG) payment system. Supporters of the bill argue that it would improve 1) patient outcomes by providing hospitals more freedom to select appropriate AM drugs and 2) financial viability of companies marketing these AM drugs. The PASTEUR Act would create a subscription payment model for new qualified AM drugs that delinks payment from sales volume. Under this model, AM drugs that meet certain criteria would earn annual U.S. government contracts valued $750 million to $3 billion. Supporters of the bill anticipate that this would reduce marketing risk, thereby incentivizing more companies to enter the AM drug development space (Presidential Advisory Council on Combating Antibiotic-resistant Bacteria, 2021).

Even though the total number of compounds in the AM pipeline may appear less than dire, according to a 2019 report from the World Health Organization (WHO), the majority of these compounds are not substantially different from existing AM drugs and do not have in vivo activity against those most worrisome MDR gram-negative bacteria as expected, based on in vitro studies conducted during development (World Health Organization, 2019).^9^ WHO (2019) further notes that the newly approved AM drugs’ “…lack of differentiation against existing treatments, …non-inclusion in clinical guidelines and …higher prices in comparison to existing generic treatments make it difficult to predict their place in the treatment landscape.” This sentiment is echoed by others who point out that some of the recently approved AM drugs appear to have no or only minor added clinical value over existing treatments (Nambiar, 2019; Schulz, et al., 2019).

2 According to data from the CDC, outpatient antibiotic prescriptions in the U.S. decreased by 10 percent from 2011 to 2018. They further decreased by 25 percent from 2019 to 2020 due to the COVID-19 pandemic, which exceeded the 15 percent reduction goal in the 2015 – 2020 Combating Antibiotic Resistant Bacteria (CARB) National Action Plan (Centers for Disease Control and Prevention, 2021).

3 The reported estimate is based on a sample size of five anti-infectives for systemic use approved during 2009–2018 period. The reported 95 percent confidence bounds around the mean estimate are $672.5 million to $1.9 billion (Wouters, et al., 2020).

4 The reported estimate in Towse et al (2017) is $1.581 in 2011 dollars. We used U.S. Medical Care Price Index to calculate the corresponding estimate in 2018 dollars (U.S. Bureau of Labor Statistics, 2021).

5 The corresponding reported estimates in Sciarretta et al. (2016) are $42.61 million, 720 million, and $1.15 billion in 2016 dollars. We used U.S. Medical Care Price Index to calculate the corresponding estimate in 2018 dollars (U.S. Bureau of Labor Statistics, 2021).

6 The figure is based on a query of the Federal Procurement Data System (FPDS) – Next Generation (NG)which is a central repository of information on Federal contracting. FPDS contains detailed information on contract actions over $3,000 (FY2004 and later data).

7 ESKAPE pathogens include Enterococcus faecium, Staphylococcus aureus, Klebsiella pneumoniae, Acinetobacter baumannii, Pseudomonas aeruginosa, and Enterobacter species (Mulani, et al., 2019). CDC urgent threat pathogens are: Clostridioides difficile, carbapenem-resistant Acinetobacter, carbapenem-resistant Enterobacterales (CRE), Candida auris, and drug-resistant Neisseria gonorrhoeae. WHO critical threat pathogens are: carbapenem-resistant Acinetobacter baumannii, carbapenem-resistant Pseudomonas aeruginosa, carbapenem-resistant ESBL-producing Enterobacteriaceae (World Health Organization, 2017).

8 For accepted new drug applications that are designated as Priority Review, FDA aims to take action within 6 months compared to 10 months under standard review (U.S. Food and Drug Administration, 2018).

9 Demonstrated in vitro activity against a pathogen during development does not always translate to similar activity in vivo for AM drugs.