# APPENDIX B SENSITIVITY ANALYSIS OF THE RELATIONSHIP BETWEEN OVERALL COMPARATIVE ADDED CLINICAL BENEFIT SCORE AND FIRST 9-QUARTER SALES

We evaluated the relationship between overall comparative added clinical benefit score and 9-quarter sales for the following cases:

▪ All AM drugs versus small company AM drugs with and without HTA metrics,
▪ All non-AM comparator drugs versus small company non-AM comparator drugs with and without HTA metrics,
▪ All oncology drugs versus large company oncology drugs with and without HTA metrics, and
▪ All oncology drugs versus those with orphan status with and without HTA metrics.

Figure B - 1 through Figure B - 6 present the results of this analysis.

Figure B - 1 First 9 Quarters of IQVIA MIDAS Reported Sales versus Overall Comparative Clinical Benefit Score – All AM and Small Company AM Drugs (Includes HTA Metrics)

Figure B - 2 First 9 Quarters of IQVIA MIDAS Reported Sales versus Overall Comparative Clinical Benefit Score – All AM and Small Company AM Drugs (Excludes HTA Metrics)

Figure B - 3 First 9 Quarters of IQVIA MIDAS Reported Sales versus Overall Comparative Clinical Benefit Score – All and Small Company Non-AM Comparator Drugs (Includes HTA Metrics)

Figure B - 4 First 9 Quarters of IQVIA MIDAS Reported Sales versus Overall Comparative Clinical Benefit Score – All and Small Company Non-AM Comparator Drugs (Excludes HTA Metrics)

Figure B - 5 First 9 Quarters of IQVIA MIDAS Reported Sales versus Overall Comparative Clinical Benefit Score – All Oncology, Large Company Oncology, and Orphan Status Oncology Drugs (Includes HTA Metrics)

Figure B - 6 First 9 Quarters of IQVIA MIDAS Reported Sales versus Overall Comparative Clinical Benefit Score – All Oncology, Large Company Oncology, and Orphan Status Oncology Drugs (Excludes HTA Metrics)