# APPENDIX A INFORMATION COMPILED ON DRUGS SELECTED FOR ANALYSIS

The following notes apply to all tables in this appendix.

[a] ESKAPE pathogens include Enterococcus faecium, Staphylococcus aureus, Klebsiella pneumoniae, Acinetobacter baumannii, Pseudomonas aeruginosa, and Enterobacter species
[b] CDC urgent threat pathogens are: Clostridioides difficile, carbapenem-resistant Enterobacteriaceae (CRE), and drug-resistant Neisseria gonorrhoeae.
[c] WHO critical threat pathogens are: carbapenem-resistant Acinetobacter baumannii, carbapenem-resistant Pseudomonas aeruginosa, carbapenem-resistant ESBL-producing Enterobacteriaceae.
[d] Therapeutic value was based on an evaluation of the incremental clinical value in comparison to the standard of care (SOC) at the time of launch, the fulfillment of unmet need, and level of innovation.
[e] Commercial performance was determined by the cumulative sales to date, projected future sales, and performance relative to analyst forecasts.
[f] The R&D investment was based on the cost of randomized clinical trials (RCTs) and duration of clinical development. Trial cost was estimated based on the total number of enrolled patients (from the drug’s NDA or BLA filing with approximate patient numbers from Post Market Requirements drawn from clinicaltrials.gov) and then adjusted for per-patient trial costs using Parexel’s biopharmaceutical statistical sourcebook. Clinical development duration was calculated based on time from the first clinical study on clinicaltrials.gov until FDA approval.
[g] The overall score represents the weighted average of therapeutic value, commercial performance, and R&D investment scores, where the weights are 40 percent, 40 percent, and 20 percent, respectively.
[h] Based on Carr and Stringer, (2019).
[i] The actual benefit (AB) of a proprietary medicinal product describes its benefit primarily in terms of its clinical efficacy and the seriousness of the condition being treated. The HAS Transparency Committee assesses the AB, which can be substantial, moderate, low, or insufficient for reimbursement for hospital use.
[j] The clinical added value (CAV) describes the improvement in treatment provided by a medicinal product compared with existing treatments. The HAS Transparency Committee assesses the degree of CAV on a scale from I (major) to IV (minor). A level V CAV means “no clinical added value”
[k] Inpatient treatment course estimates from Alan Carr's (2019) Antibiotic and Antifungal Update.
[l] The information presented for Vibativ (telavancin) is for the HABP/VABP indication and does not include that for cSSSI for which the drug received initial FDA approval for in September 2009 (outside of our study period). Thus, development and approval costs presented are underestimated as they do not incorporate the clinical work that the company would have had to undertake for initial FDA approval for cSSSI.
[m] The physical properties of Orbactiv (oritavancin) preclude incorporation into an automated AST device.

Table A - 1 Avycaz (ceftazidime-avibactam) Information

Drug Name | Avycaz (ceftazidime-avibactam)
Study Cohort | Antimicrobial
Label Indications | Indicated for the treatment of complicated urinary tract infections (cUTI) including pyelonephritis caused by the following susceptible microorganisms: Escherichia coli, Klebsiella pneumoniae, Citrobacter koseri, Enterobacter aerogenes, Enterobacter cloacae, Citrobacter freundii, Proteus spp., and Pseudomonas aeruginosa in patients 18 years or older. Also indicated for the treatment of complicated intra-abdominal infections (cIAI) in combination with metronidazole and complicated urinary tract infections (cUTI) in pediatric patients 3 months and older.
Original Company | Actavis
Current Company | Allergan
FDA Approval Date | February 2015
FDA Submission Classification | Type 1 - New Molecular Entity and Type 4 - New Combination
Type | Small molecule
Class | Cephalosporin/beta-lactamase inhibitor
Spectrum (Broad/Narrow) | Broad spectrum
Gram -negative, gram-positive, or Both | Both
Preclinical Information | Duration (in Months) | | 89
Clinical Information | Phase 1 | Number of Studies | 8
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 310
Clinical Information | Phase 1 | Total Phase Duration (in Months) | 44.9
Clinical Information | Phase 2 | Number of Studies | 1
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 204
Clinical Information | Phase 2 | Total Phase Duration (in Months) | 8.0
Clinical Information | Phase 3 | Number of Studies | 6
Clinical Information | Phase 3 | Total Enrollment (All Studies) | 3,532
Clinical Information | Phase 3 | Total Phase Duration (in Months) | 45.9
FDA Review Information | Duration (in Months) | | 8.0
Post-approval Information | Phase 4 | Number of Studies | 1
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | 12
Route of Administration | Intravenous | | Rank = 4
QIDP Designation (Yes/No) | Yes | | Rank = 1
BARDA Funding (Yes/No) | No | | Rank = 5
Type of FDA Review | Priority
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | No | | Rank = 9
Activity Against ESKAPE Pathogens (Yes/No) [a] | Yes | | Rank = 1
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | Yes | | Rank = 1
Approximate Annual Number U.S. Cases | 1.1 million | | Rank = 3
Estimated Inpatient Market Size [k] | 28,035 | | Rank = 8
Number of Drugs Available for Indication(s) in the U.S. | 39 | | Rank = 10
Trinity Drug Index | Therapeutic Score [d] | 4.2 | Rank = 1
Trinity Drug Index | Commercial Score [e] | 1.2 | Rank = 1
Trinity Drug Index | R&D Score [f] | 2.5 | Rank = 2
Trinity Drug Index | Overall Score [g] | 2.7 | Rank = 2
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | Substantial | Rank = 1
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | Minor (IV) | Rank = 3
British Health Assessment (NICE) * | Currently developing guidelines | | Rank = 4
German Dossier Assessment (IQWiG) | NA | | NA
AST Device Incorporation | Vitek^®^ 2 | Yes | Rank = 1
AST Device Incorporation | MicroScan | Yes | Rank = 1
ICER Assessment * | NA | | NA
IDSA Guideline Inclusion | HAP/VAP Guidelines; Active against Pseudomonas, effectiveness against VAP yet to be determined | | Rank = 3
P&T Community Decision * | Appropriate choice for last-line treatment / high cost | | Rank = 5
Medicaid Coverage | CA | PA | Rank = 1
Medicaid Coverage | NY | Y | Rank = 1
Medicaid Coverage | TX | Y | Rank = 1
Medicaid Coverage | PA | Y | Rank = 1
Medicaid Coverage | FL | PA | Rank = 1
Medicaid Coverage | OH | PA | Rank = 1
Medicaid Coverage | IL | Y | Rank = 1
Medicaid Coverage | MA | PPA | Rank = 1
Medicaid Coverage | MI | PA | Rank = 1
Medicaid Coverage | NJ | Y | Rank = 1
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $171.0
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $1,356.1
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 135
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 110
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $75.79

Table A - 2 Zemdri (plazomicin) Information

Drug Name | Zemdri (plazomicin)
Study Cohort | Antimicrobial
Label Indications | ZEMDRI is an aminoglycoside antibacterial indicated for the treatment of patients 18 years of age or older with Complicated Urinary Tract Infections (cUTI) including Pyelonephritis. As only limited clinical safety and efficacy data are available, reserve ZEMDRI for use in patients who have limited or no alternative treatment options. To reduce the development of drug-resistant bacteria and maintain effectiveness of ZEMDRI and other antibacterial drugs, ZEMDRI should be used only to treat infections that are proven or strongly suspected to be caused by susceptible microorganisms.
Original Company | Achaogen
Current Company | Cipla USA
FDA Approval Date | June 2018
FDA Submission Classification | Type 1 - New Molecular Entity
Type | Small molecule
Class | Aminoglycoside
Spectrum (Broad/Narrow) | Narrow spectrum
Gram -negative, gram-positive, or Both | Gram-negative
Preclinical Information | Duration (in Months) | | 93.1
Clinical Information | Phase 1 | Number of Studies | 6
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 189
Clinical Information | Phase 1 | Total Phase Duration (in Months) | 104.0
Clinical Information | Phase 2 | Number of Studies | 1
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 145
Clinical Information | Phase 2 | Total Phase Duration (in Months) | 20.7
Clinical Information | Phase 3 | Number of Studies | 2
Clinical Information | Phase 3 | Total Enrollment (All Studies) | 678
Clinical Information | Phase 3 | Total Phase Duration (in Months) | 24.2
FDA Review Information | Duration (in Months) | | 8.0
Post-approval Information | Phase 4 | Number of Studies | 0
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | NA
Route of Administration | Intravenous | | Rank = 4
QIDP Designation (Yes/No) | Yes | | Rank = 1
BARDA Funding (Yes/No) | Yes | | Rank = 1
Type of FDA Review | Priority
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | Yes | | Rank = 1
Activity Against ESKAPE Pathogens (Yes/No) [a] | No | | Rank = 12
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | Yes | | Rank = 1
Approximate Annual Number U.S. Cases | 1 million | | Rank = 6
Estimated Inpatient Market Size [k] | 28,035 | | Rank = 8
Number of Drugs Available for Indication(s) in the U.S. | 24 | | Rank = 6
Trinity Drug Index | Therapeutic Score [d] | NA | Rank = 6
Trinity Drug Index | Commercial Score [e] | NA | Rank = 6
Trinity Drug Index | R&D Score [f] | NA | Rank = 6
Trinity Drug Index | Overall Score [g] | NA | Rank = 6
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | NA | Rank = 8
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | NA | Rank = 8
British Health Assessment (NICE) * | NA | | Rank = 5
German Dossier Assessment (IQWiG) | NA | | NA
AST Device Incorporation | Vitek^®^ 2 | No | Rank = 8
AST Device Incorporation | MicroScan | No | Rank = 8
ICER Assessment * | NA | | NA
IDSA Guideline Inclusion | NA | | Rank = 8
P&T Community Decision * | NA | | Rank = 6
Medicaid Coverage | CA | N | Rank = 11
Medicaid Coverage | NY | N | Rank = 11
Medicaid Coverage | TX | N | Rank = 11
Medicaid Coverage | PA | N | Rank = 11
Medicaid Coverage | FL | N | Rank = 11
Medicaid Coverage | OH | N | Rank = 11
Medicaid Coverage | IL | N | Rank = 11
Medicaid Coverage | MA | PPA | Rank = 11
Medicaid Coverage | MI | PA | Rank = 11
Medicaid Coverage | NJ | N | Rank = 11
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $61.9
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $563.8
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 256
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 192
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $1.24

Table A - 3 Dalvance (dalbavancin) Information

Drug Name | Dalvance (dalbavancin)
Study Cohort | Antimicrobial
Label Indications | DALVANCE is indicated for acute bacterial skin and skin structure infections (ABSSSI) caused by designated susceptible strains of Gram-positive microorganisms. To reduce the development of drug-resistant bacteria and maintain the effectiveness of DALVANCE and other antibacterial drugs, DALVANCE should be used only to treat infections that are proven or strongly suspected to be caused by susceptible bacteria
Original Company | Durata Therapeutics
Current Company | Allergan
FDA Approval Date | May 2014
FDA Submission Classification | Type 1 - New Molecular Entity
Type | Small molecule
Class | Glycopeptide
Spectrum (Broad/Narrow) | Broad spectrum
Gram -negative, gram-positive, or Both | Gram-positive
Preclinical Information | Duration (in Months) | | 107.3
Clinical Information | Phase 1 | Number of Studies | 6
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 218
Clinical Information | Phase 1 | Total Phase Duration (in Months) | 30.3
Clinical Information | Phase 2 | Number of Studies | 1
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 88
Clinical Information | Phase 2 | Total Phase Duration (in Months) | 27.9
Clinical Information | Phase 3 | Number of Studies | 2
Clinical Information | Phase 3 | Total Enrollment (All Studies) | 1,312
Clinical Information | Phase 3 | Total Phase Duration (in Months) | 20.0
FDA Review Information | Duration (in Months) | | 7.8
Post-approval Information | Phase 4 | Number of Studies | 8
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | 917
Route of Administration | Intravenous | | Rank = 4
QIDP Designation (Yes/No) | Yes | | Rank = 1
BARDA Funding (Yes/No) | No | | Rank = 5
Type of FDA Review | Priority
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | Yes | | Rank = 1
Activity Against ESKAPE Pathogens (Yes/No) [a] | Yes | | Rank = 1
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | No | | Rank = 8
Approximate Annual Number U.S. Cases | 800,000 | | Rank = 8
Estimated Inpatient Market Size [k] | 302,468 | | Rank = 2
Number of Drugs Available for Indication(s) in the U.S. | 24 | | Rank = 6
Trinity Drug Index | Therapeutic Score [d] | 3 | Rank = 4
Trinity Drug Index | Commercial Score [e] | 1 | Rank = 4
Trinity Drug Index | R&D Score [f] | 1.5 | Rank = 5
Trinity Drug Index | Overall Score [g] | 9 | Rank = 5
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | Substantial | Rank = 1
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | No clinical added value (V) | Rank = 5
British Health Assessment (NICE) * | NA | | Rank = 5
German Dossier Assessment (IQWiG) | NA | | NA
AST Device Incorporation | Vitek^®^ 2 | Yes | Rank = 5
AST Device Incorporation | MicroScan | No | Rank = 5
ICER Assessment * | NA | | NA
IDSA Guideline Inclusion | SSTI Guidelines, effective treatment; OPAT Guidelines, promising | | Rank = 1
P&T Community Decision * | NA | | Rank = 6
Medicaid Coverage | CA | PA | Rank = 1
Medicaid Coverage | NY | Y | Rank = 1
Medicaid Coverage | TX | Y | Rank = 1
Medicaid Coverage | PA | Y | Rank = 1
Medicaid Coverage | FL | NPA | Rank = 1
Medicaid Coverage | OH | PA | Rank = 1
Medicaid Coverage | IL | Y | Rank = 1
Medicaid Coverage | MA | PPA | Rank = 1
Medicaid Coverage | MI | PA | Rank = 1
Medicaid Coverage | NJ | Y | Rank = 1
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $101.3
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $2,017.7
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 165
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 133
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $35.11

Table A - 4 Teflaro (ceftaroline fosamil) Information

Drug Name | Teflaro (ceftaroline fosamil)
Study Cohort | Antimicrobial
Label Indications | Teflaro^®^ is a cephalosporin antibacterial indicated in adult and pediatric patients for the treatment of the following infection caused by designated susceptible bacteria: Acute bacterial skin and skin structure infections (ABSSSI) in adult and pediatric patients (at least 34 weeks gestational age and 12 days postnatal age); Community-acquired bacterial pneumonia (CABP) in adult and pediatric patients 2 months of age and older. To reduce the development of drug-resistant bacteria and maintain the effectiveness of Teflaro and other antibacterial drugs, Teflaro should be used only to treat or prevent infections that are proven or strongly suspected to be caused by bacteria.
Original Company | Cerexa
Current Company | Allergan
FDA Approval Date | November 2010
FDA Submission Classification | Type 1 - New Molecular Entity
Type | Small molecule
Class | Cephalosporin
Spectrum (Broad/Narrow) | Broad spectrum
Gram -negative, gram-positive, or Both | Both
Preclinical Information | Duration (in Months) | | 83.6
Clinical Information | Phase 1 | Number of Studies | 12
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 237
Clinical Information | Phase 1 | Total Phase Duration (in Months) | 57.5
Clinical Information | Phase 2 | Number of Studies | 1
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 150
Clinical Information | Phase 2 | Total Phase Duration (in Months) | 5.0
Clinical Information | Phase 3 | Number of Studies | 4
Clinical Information | Phase 3 | Total Enrollment (All Studies) | 2,606
Clinical Information | Phase 3 | Total Phase Duration (in Months) | 22.0
FDA Review Information | Duration (in Months) | | 9.9
Post-approval Information | Phase 4 | Number of Studies | 13
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | 7,923
Route of Administration | Intravenous | | Rank = 4
QIDP Designation (Yes/No) | No | | Rank = 11
BARDA Funding (Yes/No) | No | | Rank = 5
Type of FDA Review | Standard
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | No | | Rank = 9
Activity Against ESKAPE Pathogens (Yes/No) [a] | Yes | | Rank = 1
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | No | | Rank = 8
Approximate Annual Number U.S. Cases | 2.5 million | | Rank = 1
Estimated Inpatient Market Size [k] | 302,468 | | Rank = 2
Number of Drugs Available for Indication(s) in the U.S. | 17 | | Rank = 1
Trinity Drug Index | Therapeutic Score [d] | NA | Rank = 6
Trinity Drug Index | Commercial Score [e] | NA | Rank = 6
Trinity Drug Index | R&D Score [f] | NA | Rank = 6
Trinity Drug Index | Overall Score [g] | NA | Rank = 6
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | Substantial (ABSSSI), Insufficient (CAP) | Rank = 7
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | Minor (IV) | Rank = 3
British Health Assessment (NICE) * | NA | | Rank = 5
German Dossier Assessment (IQWiG) | NA | | NA
AST Device Incorporation | Vitek^®^ 2 | Yes | Rank = 1
AST Device Incorporation | MicroScan | Yes | Rank = 1
ICER Assessment * | NA | | NA
IDSA Guideline Inclusion | SSTI Guidelines, should be added to initial empiric regimen when vancomycin is not an option; HABP/VABP Guidelines, No evaluations | | Rank = 3
P&T Community Decision * | NA | | Rank = 6
Medicaid Coverage | CA | PA | Rank = 7
Medicaid Coverage | NY | Y | Rank = 7
Medicaid Coverage | TX | Y; OT | Rank = 7
Medicaid Coverage | PA | Y | Rank = 7
Medicaid Coverage | FL | PA | Rank = 7
Medicaid Coverage | OH | PA | Rank = 7
Medicaid Coverage | IL | Y | Rank = 7
Medicaid Coverage | MA | PPA | Rank = 7
Medicaid Coverage | MI | PA | Rank = 7
Medicaid Coverage | NJ | Y | Rank = 7
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $214.8
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $1,888.1
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 210
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 165
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $66.41

Table A - 5 Vabomere (meropenem and vaborbactam) Information

Drug Name | Vabomere (meropenem and vaborbactam)
Study Cohort | Antimicrobial
Label Indications | VABOMERE (meropenem and vaborbactam) is a combination of meropenem, a penem antibacterial, and vaborbactam, a beta-lactamase inhibitor, indicated for the treatment of patients 18 years and older with complicated urinary tract infections (cUTI) including pyelonephritis caused by designated susceptible bacteria. To reduce the development of drug-resistant bacteria and maintain the effectiveness of VABOMERE and other antibacterial drugs, VABOMERE should be used only to treat or prevent infections that are proven or strongly suspected to be caused by susceptible bacteria.
Original Company | The Medicines Company
Current Company | Melinta Therapeutics
FDA Approval Date | August 2017
FDA Submission Classification | Type 1 - New Molecular Entity and Type 4 - New Combination
Type | Small molecule
Class | Carbapenem/beta-lactamase inhibitor
Spectrum (Broad/Narrow) | Broad spectrum
Gram -negative, gram-positive, or Both | Both
Preclinical Information | Duration (in Months) | | 29.8
Clinical Information | Phase 1 | Number of Studies | 5
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 262
Clinical Information | Phase 1 | Total Phase Duration (in Months) | 20.9
Clinical Information | Phase 2 | Number of Studies | 0
Clinical Information | Phase 2 | Total Enrollment (All Studies) | NA
Clinical Information | Phase 2 | Total Phase Duration (in Months) | NA
Clinical Information | Phase 3 | Number of Studies | 2
Clinical Information | Phase 3 | Total Enrollment (All Studies) | 627
Clinical Information | Phase 3 | Total Phase Duration (in Months) | 35.6
FDA Review Information | Duration (in Months) | | 8.0
Post-approval Information | Phase 4 | Number of Studies | 0
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | NA
Route of Administration | Intravenous | | Rank = 4
QIDP Designation (Yes/No) | Yes | | Rank = 1
BARDA Funding (Yes/No) | Yes | | Rank = 1
Type of FDA Review | Priority
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | No | | Rank = 9
Activity Against ESKAPE Pathogens (Yes/No) [a] | Yes | | Rank = 1
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | Yes | | Rank = 1
Approximate Annual Number U.S. Cases | 1 million | | Rank = 6
Estimated Inpatient Market Size [k] | 28,035 | | Rank = 8
Number of Drugs Available for Indication(s) in the U.S. | 24 | | Rank = 6
Trinity Drug Index | Therapeutic Score [d] | NA | Rank = 6
Trinity Drug Index | Commercial Score [e] | NA | Rank = 6
Trinity Drug Index | R&D Score [f] | NA | Rank = 6
Trinity Drug Index | Overall Score [g] | NA | Rank = 6
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | Substantial (resistant last resort for enterobacteria), Insufficient (otherwise) | Rank = 1
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | Moderate (III) | Rank = 1
British Health Assessment (NICE) * | A potentially useful alternative for treating infections due to carbapenem-resistant enterobacteria/ may need a combination therapy which would add additional costs | | Rank = 1
German Dossier Assessment (IQWiG) | NA | | NA
AST Device Incorporation | Vitek^®^ 2 | Yes | Rank = 1
AST Device Incorporation | MicroScan | Yes | Rank = 1
ICER Assessment * | NA | | NA
IDSA Guideline Inclusion | NA | | Rank = 8
P&T Community Decision * | Important addition to CRE treatments | | Rank = 2
Medicaid Coverage | CA | PA | Rank = 1
Medicaid Coverage | NY | Y | Rank = 1
Medicaid Coverage | TX | Y | Rank = 1
Medicaid Coverage | PA | Y | Rank = 1
Medicaid Coverage | FL | NPA | Rank = 1
Medicaid Coverage | OH | PA | Rank = 1
Medicaid Coverage | IL | Y | Rank = 1
Medicaid Coverage | MA | PPA | Rank = 1
Medicaid Coverage | MI | PA | Rank = 1
Medicaid Coverage | NJ | Y | Rank = 1
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $48.3
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $346.9
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 142
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 135
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $21.81

Table A - 6 Orbactiv (oritavancin) Information

Drug Name | Orbactiv (oritavancin)
Study Cohort | Antimicrobial
Label Indications | ORBACTIV is a lipoglycopeptide antibacterial drug indicated for the treatment of adult patients with acute bacterial skin and skin structure infections caused or suspected to be caused by susceptible isolates of designated Gram-positive microorganisms. To reduce the development of drug-resistant bacteria and maintain the effectiveness of ORBACTIV and other antibacterial drugs, ORBACTIV should be used only to treat or prevent infections that are proven or strongly suspected to be caused by bacteria.
Original Company | The Medicines Company
Current Company | Melinta Therapeutics
FDA Approval Date | August 2014
FDA Submission Classification | Type 1 - New Molecular Entity
Type | Small molecule
Class | Glycopeptide
Spectrum (Broad/Narrow) | Broad spectrum
Gram -negative, gram-positive, or Both | Gram-positive
Preclinical Information | Duration (in Months) | | 30.4
Clinical Information | Phase 1 | Number of Studies | 2
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 166
Clinical Information | Phase 1 | Total Phase Duration (in Months) | 1.9
Clinical Information | Phase 2 | Number of Studies | 1
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 294
Clinical Information | Phase 2 | Total Phase Duration (in Months) | 8.0
Clinical Information | Phase 3 | Number of Studies | 2
Clinical Information | Phase 3 | Total Enrollment (All Studies) | 1,979
Clinical Information | Phase 3 | Total Phase Duration (in Months) | 29.9
FDA Review Information | Duration (in Months) | | 8.0
Post-approval Information | Phase 4 | Number of Studies | 3
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | 54
Route of Administration | Intravenous | | Rank = 4
QIDP Designation (Yes/No) | Yes | | Rank = 1
BARDA Funding (Yes/No) | No | | Rank = 5
Type of FDA Review | Priority
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | Yes | | Rank = 1
Activity Against ESKAPE Pathogens (Yes/No) [a] | Yes | | Rank = 1
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | No | | Rank = 8
Approximate Annual Number U.S. Cases | 800,000 | | Rank = 8
Estimated Inpatient Market Size [k] | 302,468 | | Rank = 2
Number of Drugs Available for Indication(s) in the U.S. | 17 | | Rank = 1
Trinity Drug Index | Therapeutic Score [d] | 3 | Rank = 4
Trinity Drug Index | Commercial Score [e] | 1 | Rank = 4
Trinity Drug Index | R&D Score [f] | 2.5 | Rank = 2
Trinity Drug Index | Overall Score [g] | 2.1 | Rank = 4
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | Substantial | Rank = 1
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | No clinical added value (V) | Rank = 5
British Health Assessment (NICE) * | NA | | Rank = 5
German Dossier Assessment (IQWiG) | NA | | NA
AST Device Incorporation [m] | Vitek^®^ 2 | No | Rank = 8
AST Device Incorporation [m] | MicroScan | No | Rank = 8
ICER Assessment * | NA | | NA
IDSA Guideline Inclusion | OPAT Guidelines, Promising but not recommended | | Rank = 6
P&T Community Decision * | A convenient one-dose treatment option | | Rank = 3
Medicaid Coverage | CA | PA | Rank = 1
Medicaid Coverage | NY | Y | Rank = 1
Medicaid Coverage | TX | Y | Rank = 1
Medicaid Coverage | PA | Y | Rank = 1
Medicaid Coverage | FL | PA | Rank = 1
Medicaid Coverage | OH | PA | Rank = 1
Medicaid Coverage | IL | Y | Rank = 1
Medicaid Coverage | MA | PPA | Rank = 1
Medicaid Coverage | MI | PA | Rank = 1
Medicaid Coverage | NJ | Y | Rank = 1
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $182.8
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $1,542.6
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 162
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 129
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $21.09

Table A - 7 Baxdela (delafloxacin) Information

Drug Name | Baxdela (delafloxacin)
Study Cohort | Antimicrobial
Label Indications | BAXDELA is a fluoroquinolone antibacterial indicated in adults for the treatment of acute bacterial skin and skin structure infections (ABSSSI) caused by designated susceptible bacteria. To reduce the development of drug-resistant bacteria and maintain the effectiveness of BAXDELA and other antibacterial drugs, BAXDELA should be used only to treat infections that are proven or strongly suspected to be caused by bacteria.
Original Company | Melinta Therapeutics
Current Company | Melinta Therapeutics
FDA Approval Date | June 2017
FDA Submission Classification | Type 1 - New Molecular Entity
Type | Small molecule
Class | Fluoroquinolone
Spectrum (Broad/Narrow) | Broad spectrum
Gram -negative, gram-positive, or Both | Both
Preclinical Information | Duration (in Months) | | 29.3
Clinical Information | Phase 1 | Number of Studies | 10
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 504
Clinical Information | Phase 1 | Total Phase Duration (in Months) | 176.7
Clinical Information | Phase 2 | Number of Studies | 2
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 406
Clinical Information | Phase 2 | Total Phase Duration (in Months) | 40.9
Clinical Information | Phase 3 | Number of Studies | 2
Clinical Information | Phase 3 | Total Enrollment (All Studies) | 1,510
Clinical Information | Phase 3 | Total Phase Duration (in Months) | 32.0
FDA Review Information | Duration (in Months) | | 8.0
Post-approval Information | Phase 4 | Number of Studies | 0
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | NA
Route of Administration | Oral & Intravenous | | Rank = 1
QIDP Designation (Yes/No) | Yes | | Rank = 1
BARDA Funding (Yes/No) | No | | Rank = 5
Type of FDA Review | Priority
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | Yes | | Rank = 1
Activity Against ESKAPE Pathogens (Yes/No) [a] | Yes | | Rank = 1
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | Yes | | Rank = 1
Approximate Annual Number U.S. Cases | 800,000 | | Rank = 8
Estimated Inpatient Market Size [k] | 302,468 | | Rank = 2
Number of Drugs Available for Indication(s) in the U.S. | 17 | | Rank = 1
Trinity Drug Index | Therapeutic Score [d] | NA | Rank = 6
Trinity Drug Index | Commercial Score [e] | NA | Rank = 6
Trinity Drug Index | R&D Score [f] | NA | Rank = 6
Trinity Drug Index | Overall Score [g] | NA | Rank = 6
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | NA | Rank = 8
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | NA | Rank = 8
British Health Assessment (NICE) * | NA | | Rank = 5
German Dossier Assessment (IQWiG) | NA | | NA
AST Device Incorporation | Vitek^®^ 2 | Yes | Rank = 5
AST Device Incorporation | MicroScan | No | Rank = 5
ICER Assessment * | NA | | NA
IDSA Guideline Inclusion | NA | | Rank = 8
P&T Community Decision * | NA | | Rank = 6
Medicaid Coverage | CA | PA | Rank = 8
Medicaid Coverage | NY | NPA | Rank = 8
Medicaid Coverage | TX | NPA | Rank = 8
Medicaid Coverage | PA | NPA | Rank = 8
Medicaid Coverage | FL | Y | Rank = 8
Medicaid Coverage | OH | NPA | Rank = 8
Medicaid Coverage | IL | Y | Rank = 8
Medicaid Coverage | MA | PPA | Rank = 8
Medicaid Coverage | MI | NPA | Rank = 8
Medicaid Coverage | NJ | Y | Rank = 8
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $140.3
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $2,158.8
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 194
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 131
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $23.51

Table A - 8 Zerbaxa (ceftolozane + tazobactam) Information

Drug Name | Zerbaxa (ceftolozane + tazobactam)
Study Cohort | Antimicrobial
Label Indications | ZERBAXA is a combination of ceftolozane, a cephalosporin antibacterial, and tazobactam, a beta-lactamase inhibitor, indicated in patients 18 years or older for the treatment of the following infections caused by designated susceptible microorganisms: Complicated Intra-abdominal Infections (cIAI), used in combination with metronidazole; Complicated Urinary Tract Infections (cUTI), Including Pyelonephritis; Hospital-acquired Bacterial Pneumonia and Ventilator-associated Bacterial Pneumonia (HABP/VABP). To reduce the development of drug-resistant bacteria and maintain the effectiveness of ZERBAXA and other antibacterial drugs, ZERBAXA should be used only to treat or prevent infections that are proven or strongly suspected to be caused by bacteria.
Original Company | Cubist Pharmaceuticals
Current Company | Merck
FDA Approval Date | December 2014
FDA Submission Classification | Type 1 - New Molecular Entity and Type 4 - New Combination
Type | Small molecule
Class | Cephalosporin/beta-lactamase inhibitor
Spectrum (Broad/Narrow) | Broad spectrum
Gram -negative, gram-positive, or Both | Both
Preclinical Information | Duration (in Months) | | 79.9
Clinical Information | Phase 1 | Number of Studies | 9
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 192
Clinical Information | Phase 1 | Total Phase Duration (in Months) | 33.0
Clinical Information | Phase 2 | Number of Studies | 1
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 122
Clinical Information | Phase 2 | Total Phase Duration (in Months) | 7.9
Clinical Information | Phase 3 | Number of Studies | 2
Clinical Information | Phase 3 | Total Enrollment (All Studies) | 1,052
Clinical Information | Phase 3 | Total Phase Duration (in Months) | 27.4
FDA Review Information | Duration (in Months) | | 7.9
Post-approval Information | Phase 4 | Number of Studies | 2
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | 33
Route of Administration | Intravenous | | Rank = 4
QIDP Designation (Yes/No) | Yes | | Rank = 1
BARDA Funding (Yes/No) | No | | Rank = 5
Type of FDA Review | Priority
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | Yes | | Rank = 1
Activity Against ESKAPE Pathogens (Yes/No) [a] | Yes | | Rank = 1
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | Yes | | Rank = 1
Approximate Annual Number U.S. Cases | 1,100,000 | | Rank = 3
Estimated Inpatient Market Size [k] | 28, 035 | | Rank = 8
Number of Drugs Available for Indication(s) in the U.S. | 39 | | Rank = 10
Trinity Drug Index | Therapeutic Score [d] | 4 | Rank = 2
Trinity Drug Index | Commercial Score [e] | 1.2 | Rank = 1
Trinity Drug Index | R&D Score [f] | 3.5 | Rank = 1
Trinity Drug Index | Overall Score [g] | 2.8 | Rank = 1
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | Substantial | Rank = 1
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | No clinical added value (V) | Rank = 5
British Health Assessment (NICE) * | A second-line option / high acquisition costs | | Rank = 2
German Dossier Assessment (IQWiG) | NA | | NA
AST Device Incorporation | Vitek^®^ 2 | No | Rank = 5
AST Device Incorporation | MicroScan | Yes | Rank = 5
ICER Assessment * | NA | | NA
IDSA Guideline Inclusion | HAP/VAP Guidelines, Active against Pseudomonas, effectiveness against VAP yet to be determined | | Rank = 3
P&T Community Decision * | NA | | Rank = 6
Medicaid Coverage | CA | PA | Rank = 1
Medicaid Coverage | NY | Y | Rank = 1
Medicaid Coverage | TX | Y | Rank = 1
Medicaid Coverage | PA | Y | Rank = 1
Medicaid Coverage | FL | PA | Rank = 1
Medicaid Coverage | OH | PA | Rank = 1
Medicaid Coverage | IL | Y | Rank = 1
Medicaid Coverage | MA | PPA | Rank = 1
Medicaid Coverage | MI | PA | Rank = 1
Medicaid Coverage | NJ | Y | Rank = 1
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $62.2
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $439.6
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 123
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 111
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $41.27

Table A - 9 Sivextro (tedizolid phosphate) Information

Drug Name | Sivextro (tedizolid phosphate)
Study Cohort | Antimicrobial
Label Indications | SIVEXTRO is an oxazolidinone-dass antibacterial drug indicated in adult and pediatric patients 12 years of age and older for the treatment of acute bacterial skin and skin structure infections (ABSSSI) caused by designated susceptible bacteria. To reduce the development of drug-resistant bacteria and maintain the effectiveness of SIVEXTRO and other antibacterial drugs, SIVEXTRO should be used only to treat or prevent infections that are proven or strongly suspected to be caused by susceptible bacteria.
Original Company | Cubist Pharmaceuticals
Current Company | Merck
FDA Approval Date | June 2014
FDA Submission Classification | Type 1 - New Molecular Entity
Type | Small molecule
Class | Oxazolidinone
Spectrum (Broad/Narrow) | Broad spectrum
Gram -negative, gram-positive, or Both | Gram-positive
Preclinical Information | Duration (in Months) | | 47.3
Clinical Information | Phase 1 | Number of Studies | 15
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 507
Clinical Information | Phase 1 | Total Phase Duration (in Months) | 55.5
Clinical Information | Phase 2 | Number of Studies | 2
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 392
Clinical Information | Phase 2 | Total Phase Duration (in Months) | 47.2
Clinical Information | Phase 3 | Number of Studies | 2
Clinical Information | Phase 3 | Total Enrollment (All Studies) | 1,333
Clinical Information | Phase 3 | Total Phase Duration (in Months) | 28.8
FDA Review Information | Duration (in Months) | | 7.9
Post-approval Information | Phase 4 | Number of Studies | 3
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | 50
Route of Administration | Oral and Intravenous | | Rank = 1
QIDP Designation (Yes/No) | Yes | | Rank = 1
BARDA Funding (Yes/No) | No | | Rank = 5
Type of FDA Review | Priority
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | Yes | | Rank = 1
Activity Against ESKAPE Pathogens (Yes/No) [a] | Yes | | Rank = 1
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | No | | Rank = 8
Approximate Annual Number U.S. Cases | 800,000 | | Rank = 8
Estimated Inpatient Market Size [k] | 302,469 | | Rank = 2
Number of Drugs Available for Indication(s) in the U.S. | 17 | | Rank = 1
Trinity Drug Index | Therapeutic Score [d] | 3.6 | Rank = 3
Trinity Drug Index | Commercial Score [e] | 1.2 | Rank = 1
Trinity Drug Index | R&D Score [f] | 2.5 | Rank = 2
Trinity Drug Index | Overall Score [g] | 2.4 | Rank = 3
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | Substantial | Rank = 1
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | No clinical added value (V) | Rank = 5
British Health Assessment (NICE) * | NA | | Rank = 5
German Dossier Assessment (IQWiG) | NA | | NA
AST Device Incorporation | Vitek^®^ 2 | No | Rank = 8
AST Device Incorporation | MicroScan | No | Rank = 8
ICER Assessment * | NA | | NA
IDSA Guideline Inclusion | SSTI Guidelines, effective treatment | | Rank = 1
P&T Community Decision * | A novel second-generation oxazolidinone; additional data are needed on the safety of this therapy when used in the setting of neutropenia | | Rank = 3
Medicaid Coverage | CA | PA | Rank = 8
Medicaid Coverage | NY | PA | Rank = 8
Medicaid Coverage | TX | NPA | Rank = 8
Medicaid Coverage | PA | Y | Rank = 8
Medicaid Coverage | FL | NPA | Rank = 8
Medicaid Coverage | OH | PA | Rank = 8
Medicaid Coverage | IL | Y | Rank = 8
Medicaid Coverage | MA | PPA | Rank = 8
Medicaid Coverage | MI | PA | Rank = 8
Medicaid Coverage | NJ | Y | Rank = 8
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $121.3
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $868.6
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 146
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 113
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $30.44

Table A - 10 Nuzyra (omadacycline) Information

Drug Name | Nuzyra (omadacycline)
Study Cohort | Antimicrobial
Label Indications | NUZYRA is a tetracycline class antibacterial indicated for the treatment of adult patients with the following infections caused by susceptible microorganisms: Community-acquired bacterial pneumonia (CABP); Acute bacterial skin and skin structure infections (ABSSSI). To reduce the development of drug-resistant bacteria and maintain the effectiveness of NUZYRA and other antibacterial drugs, NUZYRA should be used only to treat or prevent infections that are proven or strongly suspected to be caused by susceptible bacteria.
Original Company | Paratek Pharmaceuticals
Current Company | Paratek Pharmaceuticals
FDA Approval Date | October 2018
FDA Submission Classification | Type 1 - New Molecular Entity
Type | Small molecule
Class | Tetracycline
Spectrum (Broad/Narrow) | Broad spectrum
Gram -negative, gram-positive, or Both | Both
Preclinical Information | Duration (in Months) | | 62.0
Clinical Information | Phase 1 | Number of Studies | 4
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 156
Clinical Information | Phase 1 | Total Phase Duration (in Months) | NA(?)
Clinical Information | Phase 2 | Number of Studies | 1
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 234
Clinical Information | Phase 2 | Total Phase Duration (in Months) | 5.7
Clinical Information | Phase 3 | Number of Studies | 3
Clinical Information | Phase 3 | Total Enrollment (All Studies) | 2,164
Clinical Information | Phase 3 | Total Phase Duration (in Months) | 22.8
FDA Review Information | Duration (in Months) | | 7.9
Post-approval Information | Phase 4 | Number of Studies | 0
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | NA
Route of Administration | Oral and Intravenous | | Rank = 1
QIDP Designation (Yes/No) | Yes | | Rank = 1
BARDA Funding (Yes/No) | Yes | | Rank = 1
Type of FDA Review | Priority
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | Yes | | Rank = 1
Activity Against ESKAPE Pathogens (Yes/No) [a] | Yes | | Rank = 1
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | Yes | | Rank = 1
Approximate Annual Number U.S. Cases | 2,500,000 | | Rank = 1
Estimated Inpatient Market Size [k] | 302,468 | | Rank = 2
Number of Drugs Available for Indication(s) in the U.S. | 17 | | Rank = 7
Trinity Drug Index | Therapeutic Score [d] | NA | Rank = 6
Trinity Drug Index | Commercial Score [e] | NA | Rank = 6
Trinity Drug Index | R&D Score [f] | NA | Rank = 6
Trinity Drug Index | Overall Score [g] | NA | Rank = 6
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | NA | Rank = 8
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | NA | Rank = 8
British Health Assessment (NICE) * | NA | | Rank = 5
German Dossier Assessment (IQWiG) | NA | | NA
AST Device Incorporation | Vitek^®^ 2 | No | Rank = 8
AST Device Incorporation | MicroScan | No | Rank = 8
ICER Assessment * | NA | | NA
IDSA Guideline Inclusion | NA | | Rank = 8
P&T Community Decision * | NA | | Rank = 6
Medicaid Coverage | CA | PA | Rank = 11
Medicaid Coverage | NY | NPA | Rank = 11
Medicaid Coverage | TX | NPA | Rank = 11
Medicaid Coverage | PA | NPA | Rank = 11
Medicaid Coverage | FL | Y | Rank = 11
Medicaid Coverage | OH | NPA | Rank = 11
Medicaid Coverage | IL | NPA | Rank = 11
Medicaid Coverage | MA | NPA | Rank = 11
Medicaid Coverage | MI | PA | Rank = 11
Medicaid Coverage | NJ | PA | Rank = 11
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $158.9
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $2,110.8
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 203
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 140
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $58.04

Table A - 11 Xerava (eravacycline) Information

Drug Name | Xerava (eravacycline)
Study Cohort | Antimicrobial
Label Indications | XERAVA is a tetracycline class antibacterial indicated for the treatment of complicated intra-abdominal infections in patients 18 years of age and older. Limitations of Use XERAVA is not indicated for the treatment of complicated urinary tract infections (cUTI). To reduce the development of drug-resistant bacteria and maintain the effectiveness of XERAVA and other antibacterial drugs, XERAVA should be used only to treat or prevent infections that are proven or strongly suspected to be caused by susceptible bacteria.
Original Company | Tetraphase Pharmaceuticals
Current Company | Tetraphase Pharmaceuticals
FDA Approval Date | August 2018
FDA Submission Classification | Type 1 - New Molecular Entity
Type | Small molecule
Class | Tetracycline
Spectrum (Broad/Narrow) | Broad spectrum
Gram -negative, gram-positive, or Both | Both
Preclinical Information | Duration (in Months) | | 19.6
Clinical Information | Phase 1 | Number of Studies | 9
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 227
Clinical Information | Phase 1 | Total Phase Duration (in Months) | 15.9
Clinical Information | Phase 2 | Number of Studies | 1
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 143
Clinical Information | Phase 2 | Total Phase Duration (in Months) | 15.9
Clinical Information | Phase 3 | Number of Studies | 4
Clinical Information | Phase 3 | Total Enrollment (All Studies) | 3,154
Clinical Information | Phase 3 | Total Phase Duration (in Months) | 51.9
FDA Review Information | Duration (in Months) | | 7.9
Post-approval Information | Phase 4 | Number of Studies | 0
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | NA
Route of Administration | Intravenous | | Rank = 4
QIDP Designation (Yes/No) | Yes | | Rank = 1
BARDA Funding (Yes/No) | Yes | | Rank = 1
Type of FDA Review | Priority
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | Yes | | Rank = 1
Activity Against ESKAPE Pathogens (Yes/No) [a] | Yes | | Rank = 1
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | Yes | | Rank = 1
Approximate Annual Number U.S. Cases | 100,000 | | Rank = 12
Estimated Inpatient Market Size [k] | 1,223,379 | | Rank = 1
Number of Drugs Available for Indication(s) in the U.S. | NA | | Rank = 12
Trinity Drug Index | Therapeutic Score [d] | NA | Rank = 6
Trinity Drug Index | Commercial Score [e] | NA | Rank = 6
Trinity Drug Index | R&D Score [f] | NA | Rank = 6
Trinity Drug Index | Overall Score [g] | NA | Rank = 6
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | NA | Rank = 8
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | NA | Rank = 8
British Health Assessment (NICE) * | NA | | Rank = 5
German Dossier Assessment (IQWiG) | NA | | NA
AST Device Incorporation | Vitek^®^ 2 | Yes | Rank = 1
AST Device Incorporation | MicroScan | Yes | Rank = 1
ICER Assessment * | NA | | NA
IDSA Guideline Inclusion | NA | | Rank = 8
P&T Community Decision * | NA | | Rank = 6
Medicaid Coverage | CA | N | Rank = 10
Medicaid Coverage | NY | N | Rank = 10
Medicaid Coverage | TX | N | Rank = 10
Medicaid Coverage | PA | N | Rank = 10
Medicaid Coverage | FL | Y | Rank = 10
Medicaid Coverage | OH | N | Rank = 10
Medicaid Coverage | IL | N | Rank = 10
Medicaid Coverage | MA | PPA | Rank = 10
Medicaid Coverage | MI | PA | Rank = 10
Medicaid Coverage | NJ | N | Rank = 10
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $182.7
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $1471.4
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 209
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 146
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $12.79

Table A - 12 Vibativ (telavancin) Information

Drug Name | Vibativ (telavancin) [l]
Study Cohort | Antimicrobial
Label Indications | VIBATIV is a lipoglycopeptide antibacterial drug indicated for the treatment of the following infections in adult patients caused by designated susceptible bacteria: Complicated skin and skin structure infections (cSSSI); Hospital-acquired and ventilator-associated bacterial pneumonia (HABP/VABP) caused by susceptible isolates of Staphylococcus aureus. VIBATIV should be reserved for use when alternative treatments are not suitable. To reduce the development of drug-resistant bacteria and maintain the effectiveness of VIBATIV and other antibacterial drugs VIBATIV should only be used to treat or prevent infections that are proven or strongly suspected to be caused by bacteria.
Original Company | Theravance
Current Company | Theravance
FDA Approval Date | June 2013
FDA Submission Classification | Type 1 - New Molecular Entity
Type | Small molecule
Class | Glycopeptide
Spectrum (Broad/Narrow) | Broad spectrum
Gram -negative, gram-positive, or Both | Gram-positive
Preclinical Information | Duration (in Months) | | 23.1
Clinical Information | Phase 1 | Number of Studies | 0
Clinical Information | Phase 1 | Total Enrollment (All Studies) | NA
Clinical Information | Phase 1 | Total Phase Duration (in Months) | NA
Clinical Information | Phase 2 | Number of Studies | 3
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 430
Clinical Information | Phase 2 | Total Phase Duration (in Months) | 38.0
Clinical Information | Phase 3 | Number of Studies | 4
Clinical Information | Phase 3 | Total Enrollment (All Studies) | 3,429
Clinical Information | Phase 3 | Total Phase Duration (in Months) | 29.9
FDA Review Information | Duration (in Months) | | 52.8
Post-approval Information | Phase 4 | Number of Studies | 3
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | 62
Route of Administration | Intravenous | | Rank = 4
QIDP Designation (Yes/No) | No | | Rank = 11
BARDA Funding (Yes/No) | No | | Rank = 5
Type of FDA Review | Standard
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | No | | Rank = 9
Activity Against ESKAPE Pathogens (Yes/No) [a] | Yes | | Rank = 1
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | No | | Rank = 8
Approximate Annual Number U.S. Cases | 1,100,000 | | Rank = 3
Estimated Inpatient Market Size [k] | NA | | Rank = 12
Number of Drugs Available for Indication(s) in the U.S. | 32 | | Rank = 9
Trinity Drug Index | Therapeutic Score [d] | NA | Rank = 6
Trinity Drug Index | Commercial Score [e] | NA | Rank = 6
Trinity Drug Index | R&D Score [f] | NA | Rank = 6
Trinity Drug Index | Overall Score [g] | NA | Rank = 6
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | NA | Rank = 8
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | NA | Rank = 8
British Health Assessment (NICE) * | Should only be used in situations where it is known or suspected that other alternatives are not suitable | | Rank = 3
German Dossier Assessment (IQWiG) | NA | | NA
AST Device Incorporation | Vitek^®^ 2 | No | Rank = 8
AST Device Incorporation | MicroScan | No | Rank = 8
ICER Assessment * | NA | | NA
IDSA Guideline Inclusion | HAP/VAP Guidelines, Similar outcomes to vancomycin but higher mortality rates; SSTI Guidelines, May be effective but lack clinical data | | Rank = 6
P&T Community Decision * | Exceptional benefits compared with conventional therapies | | Rank = 1
Medicaid Coverage | CA | PA | Rank = 1
Medicaid Coverage | NY | Y | Rank = 1
Medicaid Coverage | TX | Y | Rank = 1
Medicaid Coverage | PA | Y | Rank = 1
Medicaid Coverage | FL | NPA | Rank = 1
Medicaid Coverage | OH | PA | Rank = 1
Medicaid Coverage | IL | Y | Rank = 1
Medicaid Coverage | MA | PPA | Rank = 1
Medicaid Coverage | MI | PA | Rank = 1
Medicaid Coverage | NJ | Y | Rank = 1
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $288.2
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $3,329.2
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 264
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 207
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $25.71

Table A - 13 Bridion (sugammadex sodium) Information

Drug Name | Bridion (sugammadex sodium)
Study Cohort | Non-Antimicrobial Comparator
Label Indications | BRIDION is indicated for the reversal of neuromuscular blockade induced by rocuronium bromide and vecuronium bromide in adults undergoing surgery
Original Company | Merck
Current Company | Merck
FDA Approval Date | December 2015
FDA Submission Classification | Type 1 - New Molecular Entity
Type | Small molecule
Preclinical Information | Duration (in Months) | | 44.9
Clinical Information | Phase 1 | Number of Studies | 6
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 208
Clinical Information | Phase 1 | Total Phase Duration (in Months) | NA
Clinical Information | Phase 2 | Number of Studies | 8
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 770
Clinical Information | Phase 2 | Total Phase Duration (in Months) | 45.6
Clinical Information | Phase 3 | Number of Studies | 12
Clinical Information | Phase 3 | Total Enrollment (All Studies) | 1,438
Clinical Information | Phase 3 | Total Phase Duration (in Months) | 32.0
FDA Review Information | Duration (in Months) | | 97.3
Post-approval Information | Phase 4 | Number of Studies | 74
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | 8,615
Route of Administration | Intravenous | | Rank = 4
QIDP Designation (Yes/No) | NA | | NA
BARDA Funding (Yes/No) | NA | | NA
Type of FDA Review | Priority
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | Yes | | Rank = 1
Activity Against ESKAPE Pathogens (Yes/No) [a] | NA | | NA
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | NA | | NA
Approximate Annual Number U.S. Cases | NA | | Rank = 5
Estimated Inpatient Market Size [k] | NA | | NA
Number of Drugs Available for Indication(s) in the U.S. | NA | | Rank = 5
Trinity Drug Index | Therapeutic Score [d] | 4.8 | Rank = 1
Trinity Drug Index | Commercial Score [e] | 2.8 | Rank = 1
Trinity Drug Index | R&D Score [f] | 3 | Rank = 2
Trinity Drug Index | Overall Score [g] | 3.6 | Rank = 1
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | Substantial | Rank = 1
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | Minor (IV) | Rank = 1
British Health Assessment (NICE) * | NA | | Rank = 3
German Dossier Assessment (IQWiG) | NA | | Rank = 2
AST Device Incorporation | Vitek^®^ 2 | NA | NA
AST Device Incorporation | MicroScan | NA | NA
ICER Assessment * | NA | | NA
IDSA Guideline Inclusion | NA | | Rank = 2
P&T Community Decision * | NA | | NA
Medicaid Coverage | CA | PA | Rank = 4
Medicaid Coverage | NY | Y | Rank = 4
Medicaid Coverage | TX | Y | Rank = 4
Medicaid Coverage | PA | Y | Rank = 4
Medicaid Coverage | FL | PA | Rank = 4
Medicaid Coverage | OH | PA | Rank = 4
Medicaid Coverage | IL | Y | Rank = 4
Medicaid Coverage | MA | PA | Rank = 4
Medicaid Coverage | MI | PA | Rank = 4
Medicaid Coverage | NJ | Y | Rank = 4
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $233.5
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $1,936.1
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 84
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 81
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $48.52

Table A - 14 Giapreza (angiotensin II) Information

Drug Name | Giapreza (angiotensin II)
Study Cohort | Non-Antimicrobial Comparator
Label Indications | GIAPREZA is a vasoconstrictor to increase blood pressure in adults with septic or other distributive shock
Original Company | La Jolla Pharmaceutical Company
Current Company | La Jolla Pharmaceutical Company
FDA Approval Date | December 2017
FDA Submission Classification | Type 1 - New Molecular Entity
Type | Small molecule
Preclinical Information | Duration (in Months) | | 57.9
Clinical Information | Phase 1 | Number of Studies | 3
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 168
Clinical Information | Phase 1 | Total Phase Duration (in Months) | 101.3
Clinical Information | Phase 2 | Number of Studies | 1
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 12
Clinical Information | Phase 2 | Total Phase Duration (in Months) | 35.9
Clinical Information | Phase 3 | Number of Studies | 5
Clinical Information | Phase 3 | Total Enrollment (All Studies) | 927
Clinical Information | Phase 3 | Total Phase Duration (in Months) | 231.6
FDA Review Information | Duration (in Months) | | 5.7
Post-approval Information | Phase 4 | Number of Studies | 1
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | 48
Route of Administration | Intravenous | | Rank = 4
QIDP Designation (Yes/No) | NA | | NA
BARDA Funding (Yes/No) | NA | | NA
Type of FDA Review | Priority
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | Yes | | Rank = 1
Activity Against ESKAPE Pathogens (Yes/No) [a] | NA | | NA
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | NA | | NA
Approximate Annual Number U.S. Cases | 1,000,000 | | Rank = 4
Estimated Inpatient Market Size [k] | NA | | NA
Number of Drugs Available for Indication(s) in the U.S. | 21 | | Rank = 1
Trinity Drug Index | Therapeutic Score [d] | NA | Rank = 3
Trinity Drug Index | Commercial Score [e] | NA | Rank = 3
Trinity Drug Index | R&D Score [f] | NA | Rank = 3
Trinity Drug Index | Overall Score [g] | NA | Rank = 3
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | NA | Rank = 3
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | NA | Rank = 3
British Health Assessment (NICE) * | NA | | Rank = 3
German Dossier Assessment (IQWiG) | NA | | Rank = 2
AST Device Incorporation | Vitek^®^ 2 | NA | NA
AST Device Incorporation | MicroScan | NA | NA
ICER Assessment * | NA | | NA
IDSA Guideline Inclusion | Chronic Kidney Disease in HIV Guidelines, Recommended when clinically feasible | | Rank = 1
P&T Community Decision * | NA | | NA
Medicaid Coverage | CA | PA | Rank = 1
Medicaid Coverage | NY | Y | Rank = 1
Medicaid Coverage | TX | Y | Rank = 1
Medicaid Coverage | PA | Y | Rank = 1
Medicaid Coverage | FL | PA | Rank = 1
Medicaid Coverage | OH | PA | Rank = 1
Medicaid Coverage | IL | Y | Rank = 1
Medicaid Coverage | MA | PA | Rank = 1
Medicaid Coverage | MI | PA | Rank = 1
Medicaid Coverage | NJ | Y | Rank = 1
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $54.5
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $4,991.6
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 89
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 88
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $31.82

Table A - 15 Surfaxin (lucinactant) Information (Discontinued in the U.S.)

Drug Name | Surfaxin (lucinactant)
Study Cohort | Non-Antimicrobial Comparator
Label Indications | SURFAXIN is indicated for the prevention of respiratory distress syndrome (RDS) in premature infants at high risk for RDS
Original Company | Discovery Laboratories
Current Company | Discovery Laboratories
FDA Approval Date | March 2012
FDA Submission Classification | Type 1 - New Molecular Entity
Type | Small molecule
Preclinical Information | Duration (in Months) | | 54.9
Clinical Information | Phase 1 | Number of Studies | 2
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 27
Clinical Information | Phase 1 | Total Phase Duration (in Months) | NA
Clinical Information | Phase 2 | Number of Studies | 1
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 2
Clinical Information | Phase 2 | Total Phase Duration (in Months) | NA
Clinical Information | Phase 3 | Number of Studies | 2
Clinical Information | Phase 3 | Total Enrollment (All Studies) | 1,302
Clinical Information | Phase 3 | Total Phase Duration (in Months) | 26.9
FDA Review Information | Duration (in Months) | | 94.6
Post-approval Information | Phase 4 | Number of Studies | 0
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | NA
Route of Administration | Intratracheal | | Rank = 4
QIDP Designation (Yes/No) | NA | | NA
BARDA Funding (Yes/No) | NA | | NA
Type of FDA Review | Standard
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | No | | Rank = 6
Activity Against ESKAPE Pathogens (Yes/No) [a] | NA | | NA
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | NA | | NA
Approximate Annual Number U.S. Cases | 1,151,969 | | Rank = 3
Estimated Inpatient Market Size [k] | NA | | NA
Number of Drugs Available for Indication(s) in the U.S. | 4 | | Rank = 4
Trinity Drug Index | Therapeutic Score [d] | NA | Rank = 3
Trinity Drug Index | Commercial Score [e] | NA | Rank = 3
Trinity Drug Index | R&D Score [f] | NA | Rank = 3
Trinity Drug Index | Overall Score [g] | NA | Rank = 3
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | NA | Rank = 3
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | NA | Rank = 3
British Health Assessment (NICE) * | NA | | Rank = 3
German Dossier Assessment (IQWiG) | NA | | Rank = 2
AST Device Incorporation | Vitek^®^ 2 | NA | NA
AST Device Incorporation | MicroScan | NA | NA
ICER Assessment * | NA | | NA
IDSA Guideline Inclusion | NA | | Rank = 2
P&T Community Decision * | NA | | NA
Medicaid Coverage | CA | PA | Rank = 1
Medicaid Coverage | NY | Y | Rank = 1
Medicaid Coverage | TX | Y | Rank = 1
Medicaid Coverage | PA | Y | Rank = 1
Medicaid Coverage | FL | PA | Rank = 1
Medicaid Coverage | OH | PA | Rank = 1
Medicaid Coverage | IL | Y | Rank = 1
Medicaid Coverage | MA | PA | Rank = 1
Medicaid Coverage | MI | PA | Rank = 1
Medicaid Coverage | NJ | Y | Rank = 1
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $92.7
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $1,523.6
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 105
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 103
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $0.57

Table A - 16 Lokelma (sodium zirconium cyclosilicate) Information

Drug Name | Lokelma (sodium zirconium cyclosilicate)
Study Cohort | Non-Antimicrobial Comparator
Label Indications | LOKELMA is a potassium binder indicated for the treatment of hyperkalemia in adults
Original Company | AstraZeneca
Current Company | AstraZeneca
FDA Approval Date | May 2018
FDA Submission Classification | Type 1 - New Molecular Entity
Type | Small molecule
Preclinical Information | Duration (in Months) | | 125.1
Clinical Information | Phase 1 | Number of Studies | 3
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 367
Clinical Information | Phase 1 | Total Phase Duration (in Months) | 49.9
Clinical Information | Phase 2 | Number of Studies | 1
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 90
Clinical Information | Phase 2 | Total Phase Duration (in Months) | 6.0
Clinical Information | Phase 3 | Number of Studies | 4
Clinical Information | Phase 3 | Total Enrollment (All Studies) | 1,886
Clinical Information | Phase 3 | Total Phase Duration (in Months) | 47.9
FDA Review Information | Duration (in Months) | | 35.7
Post-approval Information | Phase 4 | Number of Studies | 1
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | 20
Route of Administration | Oral | | Rank = 1
QIDP Designation (Yes/No) | NA | | NA
BARDA Funding (Yes/No) | NA | | NA
Type of FDA Review | Standard
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | Yes | | Rank = 1
Activity Against ESKAPE Pathogens (Yes/No) [a] | NA | | NA
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | NA | | NA
Approximate Annual Number U.S. Cases | 3,700,000 | | Rank = 1
Estimated Inpatient Market Size [k] | NA | | NA
Number of Drugs Available for Indication(s) in the U.S. | 12 | | Rank = 2
Trinity Drug Index | Therapeutic Score [d] | NA | Rank = 3
Trinity Drug Index | Commercial Score [e] | NA | Rank = 3
Trinity Drug Index | R&D Score [f] | NA | Rank = 3
Trinity Drug Index | Overall Score [g] | NA | Rank = 3
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [il | NA | Rank = 3
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | NA | Rank = 3
British Health Assessment (NICE) * | Recommended | | Rank = 1
German Dossier Assessment (IQWiG) | NA | | Rank = 2
AST Device Incorporation | Vitek^®^ 2 | NA | NA
AST Device Incorporation | MicroScan | NA | NA
ICER Assessment * | NA | | NA
IDSA Guideline Inclusion | NA | | NA
P&T Community Decision * | NA | | NA
Medicaid Coverage | CA | PA | Rank = 4
Medicaid Coverage | NY | Y | Rank = 4
Medicaid Coverage | TX | Y; OT | Rank = 4
Medicaid Coverage | PA | PPA | Rank = 4
Medicaid Coverage | FL | PA | Rank = 4
Medicaid Coverage | OH | PA | Rank = 4
Medicaid Coverage | IL | NPA | Rank = 4
Medicaid Coverage | MA | PPA | Rank = 4
Medicaid Coverage | MI | PA | Rank = 4
Medicaid Coverage | NJ | Y | Rank = 4
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $123.3
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $1,656.0
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 78
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 76
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $88.02

Table A - 17 Veltassa (patiromer) Information

Drug Name | Veltassa (patiromer)
Study Cohort | Non-Antimicrobial Comparator
Label Indications | Veltassa is a potassium binder indicated for the treatment of hyperkalemia. Limitation of Use: Veltassa should not be used as an emergency treatment for lifethreatening hyperkalemia because of its delayed onset of action.
Original Company | Relypsa, Inc.
Current Company | Vifor Pharma, Inc.
FDA Approval Date | October 2015
FDA Submission Classification | Type 1 - New Molecular Entity
Type | Small molecule
Preclinical Information | Duration (in Months) | | 44.3
Clinical Information | Phase 1 | Number of Studies | 3
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 70
Clinical Information | Phase 1 | Total Phase Duration (in Months) | NA
Clinical Information | Phase 2 | Number of Studies | 3
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 507
Clinical Information | Phase 2 | Total Phase Duration (in Months) | 48.9
Clinical Information | Phase 3 | Number of Studies | 1
Clinical Information | Phase 3 | Total Enrollment (All Studies) | 243
Clinical Information | Phase 3 | Total Phase Duration (in Months) | 5.0
FDA Review Information | Duration (in Months) | | 12.0
Post-approval Information | Phase 4 | Number of Studies | 6
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | 2,222
Route of Administration | Oral | | Rank = 1
QIDP Designation (Yes/No) | NA | | NA
BARDA Funding (Yes/No) | NA | | NA
Type of FDA Review | Standard
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | Yes | | Rank = 1
Activity Against ESKAPE Pathogens (Yes/No) [a] | NA | | NA
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | NA | | NA
Approximate Annual Number U.S. Cases | 3,700,000 | | Rank = 1
Estimated Inpatient Market Size [k] | NA | | NA
Number of Drugs Available for Indication(s) in the U.S. | 12 | | Rank = 2
Trinity Drug Index | Therapeutic Score [d] | 3.8 | Rank = 2
Trinity Drug Index | Commercial Score [e] | 1.6 | Rank = 2
Trinity Drug Index | R&D Score [f] | 4 | Rank = 1
Trinity Drug Index | Overall Score [g] | 3 | Rank = 2
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | Substantial | Rank = 1
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | No clinical added value (V) | Rank = 2
British Health Assessment (NICE) * | Recommended | | Rank = 1
German Dossier Assessment (IQWiG) | No proof of added benefit | | Rank = 1
AST Device Incorporation | Vitek^®^ 2 | NA | NA
AST Device Incorporation | MicroScan | NA | NA
ICER Assessment * | NA | | NA
IDSA Guideline Inclusion | NA | | Rank = 2
P&T Community Decision * | NA | | NA
Medicaid Coverage | CA | PA | Rank = 6
Medicaid Coverage | NY | Y | Rank = 6
Medicaid Coverage | TX | Y; OT | Rank = 6
Medicaid Coverage | PA | PPA | Rank = 6
Medicaid Coverage | FL | NPA | Rank = 6
Medicaid Coverage | OH | PA | Rank = 6
Medicaid Coverage | IL | NPA | Rank = 6
Medicaid Coverage | MA | P; QL | Rank = 6
Medicaid Coverage | MI | PA | Rank = 6
Medicaid Coverage | NJ | P | Rank = 6
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $55.1
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $335.1
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 61
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 59
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $34.32

Table A - 18 Vistogard (uridine triacetate) Information

Drug Name | Vistogard (uridine triacetate)
Study Cohort | Non-Antimicrobial Comparator
Label Indications | VISTOGARD^®^ is a pyrimidine analog indicated for the emergency treatment of adult and pediatric patients: following a fluorouracil or capecitabine overdose regardless of the presence of symptoms, or who exhibit early-onset, severe or life-threatening toxicity affecting the cardiac or central nervous system, and/ or early onset, unusually severe adverse reactions (e.g., gastrointestinal toxicity and/or neutropenia) within 96 hours following the end of fluorouracil or capecitabine administration. Limitations of use: VISTOGARD is not recommended for the non-emergent treatment of adverse reactions associated with fluorouracil or capecitabine because it may diminish the efficacy of these drugs. The safety and efficacy of VISTOGARD initiated more than 96 hours following the end of fluorouracil or capecitabine administration have not been established.
Original Company | Wellstat Therapeutics
Current Company | Wellstat Therapeutics
FDA Approval Date | December 2015
FDA Submission Classification | NA
Type | Small molecule
Preclinical Information | Duration (in Months) | | 51.4
Clinical Information | Phase 1 | Number of Studies | 5
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 88
Clinical Information | Phase 1 | Total Phase Duration (in Months) | NA
Clinical Information | Phase 2 | Number of Studies | 2
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 85
Clinical Information | Phase 2 | Total Phase Duration (in Months) | 70.9
Clinical Information | Phase 3 | Number of Studies | 4
Clinical Information | Phase 3 | Total Enrollment (All Studies) | 389
Clinical Information | Phase 3 | Total Phase Duration (in Months) | 230.5
FDA Review Information | Duration (in Months) | | 5.0
Post-approval Information | Phase 4 | Number of Studies | 1
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | 60
Route of Administration | Oral | | Rank = 1
QIDP Designation (Yes/No) | NA | | NA
BARDA Funding (Yes/No) | NA | | NA
Type of FDA Review | Priority; Orphan
New Molecular Entity (Yes/No) | No | | Rank = 6
New Chemical Entity (Yes/No) | Yes | | Rank = 1
Activity Against ESKAPE Pathogens (Yes/No) [a] | NA | | NA
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | NA | | NA
Approximate Annual Number U.S. Cases | NA | | Rank = 5
Estimated Inpatient Market Size [k] | NA | | NA
Number of Drugs Available for Indication(s) in the U.S. | 0 | | Rank = 5
Trinity Drug Index | Therapeutic Score [d] | NA | Rank = 3
Trinity Drug Index | Commercial Score [e] | NA | Rank = 3
Trinity Drug Index | R&D Score [f] | NA | Rank = 3
Trinity Drug Index | Overall Score [g] | NA | Rank = 3
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | NA | Rank = 3
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | NA | Rank = 3
British Health Assessment (NICE) * | NA | | Rank = 3
German Dossier Assessment (IQWiG) | NA | | Rank = 2
AST Device Incorporation | Vitek^®^ 2 | NA | NA
AST Device Incorporation | MicroScan | NA | NA
ICER Assessment * | NA | | NA
IDSA Guideline Inclusion | NA | | Rank = 2
P&T Community Decision * | NA | | NA
Medicaid Coverage | CA | PA | Rank = 1
Medicaid Coverage | NY | Y | Rank = 1
Medicaid Coverage | TX | Y | Rank = 1
Medicaid Coverage | PA | Y | Rank = 1
Medicaid Coverage | FL | PA | Rank = 1
Medicaid Coverage | OH | PA | Rank = 1
Medicaid Coverage | IL | Y | Rank = 1
Medicaid Coverage | MA | PA | Rank = 1
Medicaid Coverage | MI | Y | Rank = 1
Medicaid Coverage | NJ | Y | Rank = 1
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $66.4
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $8,747.6
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 100
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 97
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $3.66

Table A - 19 Zelboraf (vemurafenib) Information

Drug Name | Zelboraf (vemurafenib)
Study Cohort | Oncology
Label Indications | ZELBORAF^®^ is a kinase inhibitor indicated for the treatment of patients with unresectable or metastatic melanoma with BRAF V600E mutation as detected by an FDA-approved test. ZELBORAF^®^ is indicated for the treatment of patients with ErdheimChester Disease with BRAF V600 mutation. Limitation of Use: ZELBORAF is not indicated for treatment of patients with wild-type BRAF melanoma.
Original Company | Hoffmann-La Roche Inc.
Current Company | Genentech Inc.
FDA Approval Date | August 2011
FDA Submission Classification | Type 1 - New Molecular Entity
Type | Small molecule
Preclinical Information | Duration (in Months) | | 32.4
Clinical Information | Phase 1 | Number of Studies | 2
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 127
Clinical Information | Phase 1 | Total Phase Duration (in Months) | NA
Clinical Information | Phase 2 | Number of Studies | 1
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 132
Clinical Information | Phase 2 | Total Phase Duration (in Months) | 11.9
Clinical Information | Phase 3 | Number of Studies | 2
Clinical Information | Phase 3 | Total Enrollment (All Studies) | 2,894
Clinical Information | Phase 3 | Total Phase Duration (in Months) | 72.6
FDA Review Information | Duration (in Months) | | 3.7
Post-approval Information | Phase 4 | Number of Studies | 2
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | 510
Route of Administration | Oral | | Rank = 1
QIDP Designation (Yes/No) | NA | | NA
BARDA Funding (Yes/No) | NA | | NA
Type of FDA Review | Priority; Orphan
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | No | | Rank = 5
Activity Against ESKAPE Pathogens (Yes/No) [a] | NA | | NA
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | NA | | NA
Approximate Annual Number U.S. Cases | 96,480 | | Rank = 7
Estimated Inpatient Market Size [k] | NA | | NA
Number of Drugs Available for Indication(s) in the U.S. | 17 | | Rank = 4
Trinity Drug Index | Therapeutic Score [d] | NA | Rank = 7
Trinity Drug Index | Commercial Score [e] | NA | Rank = 7
Trinity Drug Index | R&D Score [f] | NA | Rank = 7
Trinity Drug Index | Overall Score [g] | NA | Rank = 7
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | Substantial | Rank = 1
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | Moderate (III) | Rank = 1
British Health Assessment (NICE) * | Recommended | | Rank = 1
German Dossier Assessment (IQWiG) | Considerable added benefit | | Rank = 1
AST Device Incorporation | Vitek^®^ 2 | NA | NA
AST Device Incorporation | MicroScan | NA | NA
ICER Assessment * | NA | | Rank = 4
IDSA Guideline Inclusion | NA | | NA
P&T Community Decision * | NA | | Rank = 4
Medicaid Coverage | CA | P | Rank = 1
Medicaid Coverage | NY | Y | Rank = 1
Medicaid Coverage | TX | Y; OT | Rank = 1
Medicaid Coverage | PA | PPA | Rank = 1
Medicaid Coverage | FL | PPA | Rank = 1
Medicaid Coverage | OH | Y | Rank = 1
Medicaid Coverage | IL | NPA | Rank = 1
Medicaid Coverage | MA | PPA | Rank = 1
Medicaid Coverage | MI | Y | Rank = 1
Medicaid Coverage | NJ | P | Rank = 1
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $260.0
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $1,596.2
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 126.8
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 118.0
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $475.31

Table A - 20 Stivarga (regorafenib) Information

Drug Name | Stivarga (regorafenib)
Study Cohort | Oncology
Label Indications | STIVARGA is a kinase inhibitor indicated for the treatment of patients with: Metastatic colorectal cancer (CRC) who have been previously treated with fluoropyrimidine-, oxaliplatin-and irinotecan-based chemotherapy, an antiVEGF therapy, and, if RAS wild-type, an anti-EGFR therapy; Locally advanced, unresectable or metastatic gastrointestinal stromal tumor (GIST) who have been previously treated with imatinib mesylate and sunitinib malate; Hepatocellular carcinoma (HCC) who have been previously treated with sorafenib.
Original Company | Bayer HealthCare Pharmaceuticals, Inc.
Current Company | Bayer
FDA Approval Date | August 2011
FDA Submission Classification | Type 1 - New Molecular Entity
Type | Small molecule
Preclinical Information | Duration (in Months) | | 90.0
Clinical Information | Phase 1 | Number of Studies | 8
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 260
Clinical Information | Phase 1 | Total Phase Duration (in Months) | 33.9
Clinical Information | Phase 2 | Number of Studies | 4
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 173
Clinical Information | Phase 2 | Total Phase Duration (in Months) | 49.9
Clinical Information | Phase 3 | Number of Studies | 2
Clinical Information | Phase 3 | Total Enrollment (All Studies) | 959
Clinical Information | Phase 3 | Total Phase Duration (in Months) | 20.9
FDA Review Information | Duration (in Months) | | 5.0
Post-approval Information | Phase 4 | Number of Studies | 2
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | 131
Route of Administration | Oral | | Rank = 1
QIDP Designation (Yes/No) | NA | | NA
BARDA Funding (Yes/No) | NA | | NA
Type of FDA Review | Priority; Orphan
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | No | | Rank = 5
Activity Against ESKAPE Pathogens (Yes/No) [a] | NA | | NA
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | NA | | NA
Approximate Annual Number U.S. Cases | 192,630 | | Rank = 5
Estimated Inpatient Market Size [k] | NA | | NA
Number of Drugs Available for Indication(s) in the U.S. | 21 | | Rank = 6
Trinity Drug Index | Therapeutic Score [d] | NA | Rank = 7
Trinity Drug Index | Commercial Score [e] | NA | Rank = 7
Trinity Drug Index | R&D Score [f] | NA | Rank = 7
Trinity Drug Index | Overall Score [g] | NA | Rank = 7
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | Substantial (with sorafenib tolerance), Insufficient (other clinical situations) | Rank = 8
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | Minor (IV) | Rank = 4
British Health Assessment (NICE) * | Recommended | | Rank = 1
German Dossier Assessment (IQWiG) | Minor added benefit | | Rank = 3
AST Device Incorporation | Vitek^®^ 2 | NA | NA
AST Device Incorporation | MicroScan | NA | NA
ICER Assessment * | NA | | Rank = 4
IDSA Guideline Inclusion | NA | | NA
P&T Community Decision * | NA | | Rank = 4
Medicaid Coverage | CA | P | Rank = 2
Medicaid Coverage | NY | Y | Rank = 2
Medicaid Coverage | TX | Y; OT | Rank = 2
Medicaid Coverage | PA | PPA | Rank = 2
Medicaid Coverage | FL | NPA | Rank = 2
Medicaid Coverage | OH | PA | Rank = 2
Medicaid Coverage | IL | NPA | Rank = 2
Medicaid Coverage | MA | PPA | Rank = 2
Medicaid Coverage | MI | Y | Rank = 2
Medicaid Coverage | NJ | Y | Rank = 2
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $123.0
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $3,761.5
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 163.5
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 120.0
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $241.91

Table A - 21 Erivedge (vismodegib) Information

Drug Name | Erivedge (vismodegib)
Study Cohort | Oncology
Label Indications | ERIVEDGE (vismodegib) is a hedgehog pathway inhibitor indicated for the treatment of adults with metastatic basal cell carcinoma, or with locally advanced basal cell carcinoma that has recurred following surgery or who are not candidates for surgery and who are not candidates for radiation.
Original Company | Genentech, Inc.
Current Company | Genentech, Inc.
FDA Approval Date | lanuary 2012
FDA Submission Classification | Type 1 - New Molecular Entity
Type | Small molecule
Preclinical Information | Duration (in Months) | | 24.8
Clinical Information | Phase 1 | Number of Studies | 4
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 220
Clinical Information | Phase 1 | Total Phase Duration (in Months) | 46.5
Clinical Information | Phase 2 | Number of Studies | 3
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 407
Clinical Information | Phase 2 | Total Phase Duration (in Months) | 31.0
Clinical Information | Phase 3 | Number of Studies | 0
Clinical Information | Phase 3 | Total Enrollment (All Studies) | NA
Clinical Information | Phase 3 | Total Phase Duration (in Months) | NA
FDA Review Information | Duration (in Months) | | 4.7
Post-approval Information | Phase 4 | Number of Studies | 2
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | 65
Route of Administration | Oral | | Rank = 1
QIDP Designation (Yes/No) | NA | | NA
BARDA Funding (Yes/No) | NA | | NA
Type of FDA Review | Priority
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | No | | Rank = 5
Activity Against ESKAPE Pathogens (Yes/No) [a] | NA | | NA
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | NA | | NA
Approximate Annual Number U.S. Cases | 2,800,000 | | Rank = 1
Estimated Inpatient Market Size [k] | NA | | NA
Number of Drugs Available for Indication(s) in the U.S. | 7 | | Rank = 3
Trinity Drug Index | Therapeutic Score [d] | NA | Rank = 7
Trinity Drug Index | Commercial Score [e] | NA | Rank = 7
Trinity Drug Index | R&D Score [f] | NA | Rank = 7
Trinity Drug Index | Overall Score [g] | NA | Rank = 7
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | Substantial | Rank = 1
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | Minor (IV) | Rank = 4
British Health Assessment (NICE) * | Not recommended | | Rank = 11
German Dossier Assessment (IQWiG) | Added benefit not proven | | Rank = 8
AST Device Incorporation | Vitek^®^ 2 | NA | NA
AST Device Incorporation | MicroScan | NA | NA
ICER Assessment * | NA | | Rank = 4
IDSA Guideline Inclusion | NA | | NA
P&T Community Decision * | Important new therapy | | Rank = 1
Medicaid Coverage | CA | P | Rank = 2
Medicaid Coverage | NY | Y | Rank = 2
Medicaid Coverage | TX | Y; OT | Rank = 2
Medicaid Coverage | PA | PPA | Rank = 2
Medicaid Coverage | FL | NPA | Rank = 2
Medicaid Coverage | OH | PA | Rank = 2
Medicaid Coverage | IL | P | Rank = 2
Medicaid Coverage | MA | PPA | Rank = 2
Medicaid Coverage | MI | Y | Rank = 2
Medicaid Coverage | NJ | Y | Rank = 2
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $55.0
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $1,321.3
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 162.8
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 96.5
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $118.32

Table A - 22 Ibrance (palbociclib) Information

Drug Name | Ibrance (palbociclib)
Study Cohort | Oncology
Label Indications | IBRANCE is a kinase inhibitor indicated for the treatment of adult patients with hormone receptor (HR)-positive, human epidermal growth factor receptor 2 (HER2)-negative advanced or metastatic breast cancer in combination with: an aromatase inhibitor as initial endocrine-based therapy in postmenopausal women or in men; or fulvestrant in patients with disease progression following endocrine therapy.
Original Company | Pfizer Inc.
Current Company | Pfizer Inc.
FDA Approval Date | December 2015
FDA Submission Classification | Type 1 - New Molecular Entity
Type | Small molecule
Preclinical Information | Duration (in Months) | | 25.5
Clinical Information | Phase 1 | Number of Studies | 15
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 454
Clinical Information | Phase 1 | Total Phase Duration (in Months) | 116.7
Clinical Information | Phase 2 | Number of Studies | 4
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 294
Clinical Information | Phase 2 | Total Phase Duration (in Months) | 72.8
Clinical Information | Phase 3 | Number of Studies | 4
Clinical Information | Phase 3 | Total Enrollment (All Studies) | 3,033
Clinical Information | Phase 3 | Total Phase Duration (in Months) | 94.1
FDA Review Information | Duration (in Months) | | 5.7
Post-approval Information | Phase 4 | Number of Studies | 4
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | 1,623
Route of Administration | Oral | | Rank = 1
QIDP Designation (Yes/No) | NA | | NA
BARDA Funding (Yes/No) | NA | | NA
Type of FDA Review | Priority
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | Yes | | Rank = 1
Activity Against ESKAPE Pathogens (Yes/No) [a] | NA | | NA
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | NA | | NA
Approximate Annual Number U.S. Cases | 271,270 | | Rank = 3
Estimated Inpatient Market Size [k] | NA | | NA
Number of Drugs Available for Indication(s) in the U.S. | 35 | | Rank = 11
Trinity Drug Index | Therapeutic Score [d] | 4.6 | Rank = 2
Trinity Drug Index | Commercial Score [e] | 4.8 | Rank = 1
Trinity Drug Index | R&D Score [f] | 3.5 | Rank = 2
Trinity Drug Index | Overall Score [g] | 4.5 | Rank = 1
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | Substantial (no visceral involvement, pre-treated with endocrine therapy), Insufficient (others) | Rank = 8
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | Minor (IV), No clinical added value (V) | Rank = 9
British Health Assessment (NICE) * | Recommended with an aromatase inhibitor | | Rank = 1
German Dossier Assessment (IQWiG) | Added benefit not proven | | Rank = 8
AST Device Incorporation | Vitek^®^ 2 | NA | NA
AST Device Incorporation | MicroScan | NA | NA
ICER Assessment * | NA | | Rank = 4
IDSA Guideline Inclusion | NA | | NA
P&T Community Decision * | NA | | Rank = 4
Medicaid Coverage | CA | P | Rank = 2
Medicaid Coverage | NY | Y | Rank = 2
Medicaid Coverage | TX | Y; OT | Rank = 2
Medicaid Coverage | PA | PPA | Rank = 2
Medicaid Coverage | FL | NPA | Rank = 2
Medicaid Coverage | OH | Y | Rank = 2
Medicaid Coverage | IL | NPA | Rank = 2
Medicaid Coverage | MA | PPA | Rank = 2
Medicaid Coverage | MI | Y | Rank = 2
Medicaid Coverage | NJ | P | Rank = 2
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $323.4
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $6,050.0
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 148.2
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 75.9
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $3,551.16

Table A - 23 Portrazza (necitumumab) Information

Drug Name | Portrazza (necitumumab)
Study Cohort | Oncology
Label Indications | PORTRAZZA^™^ is an epidermal growth factor receptor (EGFR) antagonist indicated, in combination with gemcitabine and cisplatin, for first-line treatment of patients with metastatic squamous non-small cell lung cancer. Limitation of Use: PORTRAZZA is not indicated for treatment of non-squamous non-small cell lung cancer.
Original Company | Eli Lilly and Company
Current Company | Eli Lilly and Company
FDA Approval Date | November 2015
FDA Submission Classification | Type 1 - New Molecular Entity
Type | Large molecule
Preclinical Information | Duration (in Months) | | 49.7
Clinical Information | Phase 1 | Number of Studies | 2
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 75
Clinical Information | Phase 1 | Total Phase Duration (in Months) | 86.8
Clinical Information | Phase 2 | Number of Studies | 5
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 382
Clinical Information | Phase 2 | Total Phase Duration (in Months) | 91.8
Clinical Information | Phase 3 | Number of Studies | 2
Clinical Information | Phase 3 | Total Enrollment (All Studies) | 1,726
Clinical Information | Phase 3 | Total Phase Duration (in Months) | 43.4
FDA Review Information | Duration (in Months) | | 11.7
Post-approval Information | Phase 4 | Number of Studies | 0
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | NA
Route of Administration | Intra-articular, intramuscular, intravitreal | | Rank = 9
QIDP Designation (Yes/No) | NA | | NA
BARDA Funding (Yes/No) | NA | | NA
Type of FDA Review | None
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | No | | Rank = 5
Activity Against ESKAPE Pathogens (Yes/No) [a] | NA | | NA
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | NA | | NA
Approximate Annual Number U.S. Cases | 194,497 | | Rank = 4
Estimated Inpatient Market Size [k] | NA | | NA
Number of Drugs Available for Indication(s) in the U.S. | 37 | | Rank = 12
Trinity Drug Index | Therapeutic Score [d] | 3.2 | Rank = 4
Trinity Drug Index | Commercial Score [e] | 1 | Rank = 6
Trinity Drug Index | R&D Score [f] | 2.5 | Rank = 5
Trinity Drug Index | Overall Score [g] | 2.2 | Rank = 6
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | NA | Rank = 12
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | NA | Rank = 12
British Health Assessment (NICE) * | Not recommended in combination with gemcitabine and cisplatin | | Rank = 11
German Dossier Assessment (IQWiG) | Minor added benefit in combination with gemcitabine and cisplatin | | Rank = 3
AST Device Incorporation | Vitek® 2 | NA | NA
AST Device Incorporation | MicroScan | NA | NA
ICER Assessment * | NA | | Rank = 4
IDSA Guideline Inclusion | NA | | NA
P&T Community Decision * | NA | | Rank = 4
Medicaid Coverage | CA | P | Rank = 13
Medicaid Coverage | NY | N | Rank = 13
Medicaid Coverage | TX | N | Rank = 13
Medicaid Coverage | PA | N | Rank = 13
Medicaid Coverage | FL | NPA | Rank = 13
Medicaid Coverage | OH | N | Rank = 13
Medicaid Coverage | IL | N | Rank = 13
Medicaid Coverage | MA | PPA | Rank = 13
Medicaid Coverage | MI | N | Rank = 13
Medicaid Coverage | NJ | P | Rank = 13
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $176.6
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $6,331.0
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 273.3
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 165.1
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $25.31

Table A - 24 Yescarta (axicabtagene ciloleucel) Information

Drug Name | Yescarta (axicabtagene ciloleucel)
Study Cohort | Oncology
Label Indications | YESCARTA is a CD19-directed genetically modified autologous T cell immunotherapy indicated for the treatment of: Adult patients with relapsed or refractory large B-cell lymphoma after two or more lines of systemic therapy, including diffuse large B-cell lymphoma (DLBCL) not otherwise specified, primary mediastinal large B-cell lymphoma, high grade B-cell lymphoma, and DLBCL arising from follicular lymphoma. Limitations of Use: YESCARTA is not indicated for the treatment of patients with primary central nervous system lymphoma. Adult patients with relapsed or refractory follicular lymphoma (FL) after two or more lines of systemic therapy. This indication is approvedunder accelerated approval based on response rate. Continued approval for this indication may be contingent upon verification and description of clinical benefit in confirmatory trial(s).
Original Company | Kite Pharma Inc.
Current Company | Kite Pharma Inc.
FDA Approval Date | October 2017
FDA Submission Classification | Type 1 - New Molecular Entity
Type | Large molecule
Preclinical Information | Duration (in Months) | | 49.7
Clinical Information | Phase 1 | Number of Studies | 1
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 8
Clinical Information | Phase 1 | Total Phase Duration (in Months) | 21.2
Clinical Information | Phase 2 | Number of Studies | 1
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 111
Clinical Information | Phase 2 | Total Phase Duration (in Months) | 21.2
Clinical Information | Phase 3 | Number of Studies | 0
Clinical Information | Phase 3 | Total Enrollment (All Studies) | NA
Clinical Information | Phase 3 | Total Phase Duration (in Months) | NA
FDA Review Information | Duration (in Months) | | 6.6
Post-approval Information | Phase 4 | Number of Studies | 0
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | NA
Route of Administration | Intravenous | | Rank = 9
QIDP Designation (Yes/No) | NA | | NA
BARDA Funding (Yes/No) | NA | | NA
Type of FDA Review | None
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | No | | Rank = 5
Activity Against ESKAPE Pathogens (Yes/No) [a] | NA | | NA
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | NA | | NA
Approximate Annual Number U.S. Cases | 74,200 | | Rank = 9
Estimated Inpatient Market Size [k] | NA | | NA
Number of Drugs Available for Indication(s) in the U.S. | 31 | | Rank = 10
Trinity Drug Index | Therapeutic Score [d] | NA | Rank = 7
Trinity Drug Index | Commercial Score [e] | NA | Rank = 7
Trinity Drug Index | R&D Score [f] | NA | Rank = 7
Trinity Drug Index | Overall Score [g] | NA | Rank = 7
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | Substantial | Rank = 1
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | Moderate (III) | Rank = 1
British Health Assessment (NICE) * | Recommended | | Rank = 1
German Dossier Assessment (IQWiG) | NA | | Rank = 13
AST Device Incorporation | Vitek^®^ 2 | NA | NA
AST Device Incorporation | MicroScan | NA | NA
ICER Assessment * | B+ rating / net health benefit / Affordability and Access Alert | | Rank = 1
IDSA Guideline Inclusion | NA | | NA
P&T Community Decision * | NA | | Rank = 4
Medicaid Coverage | CA | PA | Rank = 14
Medicaid Coverage | NY | N | Rank = 14
Medicaid Coverage | TX | N | Rank = 14
Medicaid Coverage | PA | PA | Rank = 14
Medicaid Coverage | FL | N | Rank = 14
Medicaid Coverage | OH | N | Rank = 14
Medicaid Coverage | IL | N | Rank = 14
Medicaid Coverage | MA | MB; OT | Rank = 14
Medicaid Coverage | MI | N | Rank = 14
Medicaid Coverage | NJ | N | Rank = 14
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $16.8
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $234.8
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 218.5
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 176.0
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $343.33

Table A - 25 Braftovi (encorafenib + Mektovi [binimetinib]) Information

Drug Name | Braftovi (encorafenib + Mektovi [binimetinib])
Study Cohort | Oncology
Label Indications | BRAFTOVI is a kinase inhibitor indicated: in combination with binimetinib, for the treatment of patients with unresectable or metastatic melanoma with a BRAF V600E or V600K mutation, as detected by an FDA-approved test; in combination with cetuximab, for the treatment of adult patients with metastatic colorectal cancer (CRC) with a BRAF V600E mutation, as detected by an FDA-approved test, after prior therapy.
Original Company | Array BioPharma Inc.
Current Company | Pfizer Inc.
FDA Approval Date | June 2018
FDA Submission Classification | Type 1 - New Molecular Entity and Type 4 - New Combination
Type | Small molecule
Preclinical Information | Duration (in Months) | | 41.9
Clinical Information | Phase 1 | Number of Studies | 2
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 117
Clinical Information | Phase 1 | Total Phase Duration (in Months) | 34.5
Clinical Information | Phase 2 | Number of Studies | 4
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 219
Clinical Information | Phase 2 | Total Phase Duration (in Months) | 59.7
Clinical Information | Phase 3 | Number of Studies | 5
Clinical Information | Phase 3 | Total Enrollment (All Studies) | 2,889
Clinical Information | Phase 3 | Total Phase Duration (in Months) | 67.4
FDA Review Information | Duration (in Months) | | 11.9
Post-approval Information | Phase 4 | Number of Studies | 0
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | NA
Route of Administration | Oral | | Rank = 1
QIDP Designation (Yes/No) | NA | | NA
BARDA Funding (Yes/No) | NA | | NA
Type of FDA Review | Standard; Orphan
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | Yes | | Rank = 1
Activity Against ESKAPE Pathogens (Yes/No) [a] | NA | | NA
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | NA | | NA
Approximate Annual Number U.S. Cases | 96,480 | | Rank = 7
Estimated Inpatient Market Size [k] | NA | | NA
Number of Drugs Available for Indication(s) in the U.S. | 17 | | Rank = 4
Trinity Drug Index | Therapeutic Score [d] | NA | Rank = 7
Trinity Drug Index | Commercial Score [e] | NA | Rank = 7
Trinity Drug Index | R&D Score [f] | NA | Rank = 7
Trinity Drug Index | Overall Score [g] | NA | Rank = 7
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | Moderate | Rank = 10
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | No clinical added value (V) | Rank = 10
British Health Assessment (NICE) * | Recommended | | Rank = 1
German Dossier Assessment (IQWiG) | Added benefit not proven | | Rank = 8
AST Device Incorporation | Vitek^®^ 2 | NA | NA
AST Device Incorporation | MicroScan | NA | NA
ICER Assessment * | NA | | Rank = 4
IDSA Guideline Inclusion | NA | | NA
P&T Community Decision * | NA | | Rank = 4
Medicaid Coverage | CA | PPA | Rank = 2
Medicaid Coverage | NY | Y | Rank = 2
Medicaid Coverage | TX | Y | Rank = 2
Medicaid Coverage | PA | NPA | Rank = 2
Medicaid Coverage | FL | Y; QL | Rank = 2
Medicaid Coverage | OH | PA | Rank = 2
Medicaid Coverage | IL | NPA | Rank = 2
Medicaid Coverage | MA | PPA | Rank = 2
Medicaid Coverage | MI | Y | Rank = 2
Medicaid Coverage | NJ | Y | Rank = 2
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $266.2
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $7,208.2
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 192.8
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 113.0
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $301.69

Table A - 26 Cyramza (ramucirumab) Information

Drug Name | Cyramza (ramucirumab)
Study Cohort | Oncology
Label Indications | CYRAMZA^®^ is a human vascular endothelial growth factor receptor 2 (VEGFR2) antagonist indicated: as a single agent or in combination with paclitaxel, for treatment of advanced or metastatic gastric or gastro-esophageal junction adenocarcinoma with disease progression on or after prior fluoropyrimidine-or platinum-containing chemotherapy; in combination with erlotinib, for first-line treatment of metastatic non-small cell lung cancer with epidermal growth factor receptor (EGFR) exon 19 deletions or exon 21 (L858R) mutations; in combination with docetaxel, for treatment of metastatic non-small cell lung cancer with disease progression on or after platinum-based chemotherapy. Patients with EGFR or ALK genomic tumor aberrations should have disease progression on FDA-approved therapy for these aberrations prior to receiving CYRAMZA; in combination with FOLFIRI, for the treatment of metastatic colorectal cancer with disease progression on or after prior therapy with bevacizumab, oxaliplatin, and a fluoropyrimidine; as a single agent, for the treatment of hepatocellular carcinoma in patients who have an alpha fetoprotein of ≥400 ng/mL and have been treated with sorafenib.
Original Company | Eli Lilly and Company
Current Company | Eli Lilly and Company
FDA Approval Date | April 2014
FDA Submission Classification | Type 1 - New Molecular Entity
Type | Large molecule
Preclinical Information | Duration (in Months) | | 49.7
Clinical Information | Phase 1 | Number of Studies | 6
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 96
Clinical Information | Phase 1 | Total Phase Duration (in Months) | 93.8
Clinical Information | Phase 2 | Number of Studies | 17
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 1613
Clinical Information | Phase 2 | Total Phase Duration (in Months) | 73.9
Clinical Information | Phase 3 | Number of Studies | 6
Clinical Information | Phase 3 | Total Enrollment (All Studies) | 5,054
Clinical Information | Phase 3 | Total Phase Duration (in Months) | 71.2
FDA Review Information | Duration (in Months) | | 7.9
Post-approval Information | Phase 4 | Number of Studies | 0
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | NA
Route of Administration | Injection | | Rank = 9
QIDP Designation (Yes/No) | NA | | NA
BARDA Funding (Yes/No) | NA | | NA
Type of FDA Review | Orphan
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | No | | Rank = 5
Activity Against ESKAPE Pathogens (Yes/No) [a] | NA | | NA
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | NA | | NA
Approximate Annual Number U.S. Cases | 382,127 | | Rank = 2
Estimated Inpatient Market Size [k] | NA | | NA
Number of Drugs Available for Indication(s) in the U.S. | 83 | | Rank = 13
Trinity Drug Index | Therapeutic Score [d] | 4.2 | Rank = 3
Trinity Drug Index | Commercial Score [e] | 2.8 | Rank = 3
Trinity Drug Index | R&D Score [f] | 3 | Rank = 3
Trinity Drug Index | Overall Score [g] | 3.4 | Rank = 3
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | Moderate | Rank = 10
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | No clinical added value (V) | Rank = 10
British Health Assessment (NICE) * | Not recommended | | Rank = 11
German Dossier Assessment (IQWiG) | Minor added benefit | | Rank = 3
AST Device Incorporation | Vitek^®^ 2 | NA | NA
AST Device Incorporation | MicroScan | NA | NA
ICER Assessment * | NA | | Rank = 4
IDSA Guideline Inclusion | NA | | NA
P&T Community Decision * | Effective second-line treatment | | Rank = 2
Medicaid Coverage | CA | P | Rank = 9
Medicaid Coverage | NY | MB; 0T | Rank = 9
Medicaid Coverage | TX | Y | Rank = 9
Medicaid Coverage | PA | Y | Rank = 9
Medicaid Coverage | FL | NP | Rank = 9
Medicaid Coverage | OH | NPA | Rank = 9
Medicaid Coverage | IL | Y | Rank = 9
Medicaid Coverage | MA | PPA | Rank = 9
Medicaid Coverage | MI | Y | Rank = 9
Medicaid Coverage | NJ | P | Rank = 9
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $651.5
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $19,731.2
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 227.7
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 130.7
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $760.30

Table A - 27 Darzalex (daratumumab) Information

Drug Name | Darzalex (daratumumab)
Study Cohort | Oncology
Label Indications | DARZALEX is a CD38-directed cytolytic antibody indicated for the treatment of adult patients with multiple myeloma: in combination with lenalidomide and dexamethasone in newly diagnosed patients who are ineligible for autologous stem cell transplant and in patients with relapsed or refractory multiple myeloma who have received at least one prior therapy; in combination with bortezomib, melphalan and prednisone in newly diagnosed patients who are ineligible for autologous stem cell transplant; in combination with bortezomib, thalidomide, and dexamethasone in newly diagnosed patients who are eligible for autologous stem cell transplant; in combination with bortezomib and dexamethasone in patients who have received at least one prior therapy; in combination with carfilzomib and dexamethasone in patients with relapsed or refractory multiple myeloma who have received one to three prior lines of therapy; in combination with pomalidomide and dexamethasone in patients who have received at least two prior therapies including lenalidomide and a proteasome inhibitor; as monotherapy, in patients who have received at least three prior lines of therapy including a proteasome inhibitor (PI) and an immunomodulatory agent or who are double-refractory to a PI and an immunomodulatory agent.
Original Company | Janssen Biotech, Inc.
Current Company | Janssen Biotech, Inc.
FDA Approval Date | November 2015
FDA Submission Classification | Type 1 - New Molecular Entity
Type | Large molecule
Preclinical Information | Duration (in Months) | | 49.7
Clinical Information | Phase 1 | Number of Studies | 1
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 9
Clinical Information | Phase 1 | Total Phase Duration (in Months) | 17.0
Clinical Information | Phase 2 | Number of Studies | 2
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 228
Clinical Information | Phase 2 | Total Phase Duration (in Months) | 81.3
Clinical Information | Phase 3 | Number of Studies | 4
Clinical Information | Phase 3 | Total Enrollment (All Studies) | 2,511
Clinical Information | Phase 3 | Total Phase Duration (in Months) | 52.0
FDA Review Information | Duration (in Months) | | 4.3
Post-approval Information | Phase 4 | Number of Studies | 1
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | 150
Route of Administration | Injection | | Rank = 9
QIDP Designation (Yes/No) | NA | | NA
BARDA Funding (Yes/No) | NA | | NA
Type of FDA Review | Orphan
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | No | | Rank = 5
Activity Against ESKAPE Pathogens (Yes/No) [a] | NA | | NA
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | NA | | NA
Approximate Annual Number U.S. Cases | 32,110 | | Rank = 10
Estimated Inpatient Market Size [k] | NA | | NA
Number of Drugs Available for Indication(s) in the U.S. | 23 | | Rank = 8
Trinity Drug Index | Therapeutic Score [d] | 4.8 | Rank = 1
Trinity Drug Index | Commercial Score [e] | 4.6 | Rank = 2
Trinity Drug Index | R&D Score [f] | 3 | Rank = 3
Trinity Drug Index | Overall Score [g] | 4.4 | Rank = 2
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | Substantial | Rank = 1
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | Minor (IV) | Rank = 4
British Health Assessment (NICE) * | Recommended | | Rank = 1
German Dossier Assessment (IQWiG) | Non-quantifiable added benefit | | Rank = 6
AST Device Incorporation | Vitek^®^ 2 | NA | NA
AST Device Incorporation | MicroScan | NA | NA
ICER Assessment * | I rating / “reasonable” cost value/ Insufficient evidence for net health benefit | | Rank = 3
IDSA Guideline Inclusion | NA | | NA
P&T Community Decision * | NA | | Rank = 4
Medicaid Coverage | CA | P | Rank = 9
Medicaid Coverage | NY | MB; OT | Rank = 9
Medicaid Coverage | TX | Y | Rank = 9
Medicaid Coverage | PA | Y | Rank = 9
Medicaid Coverage | FL | NPA | Rank = 9
Medicaid Coverage | OH | PA | Rank = 9
Medicaid Coverage | IL | Y | Rank = 9
Medicaid Coverage | MA | PPA | Rank = 9
Medicaid Coverage | MI | N | Rank = 9
Medicaid Coverage | NJ | Y | Rank = 9
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $195.7
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $3,000.9
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 164.3
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 131.8
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $1,709.53

Table A - 28 Vitrakvi (larotrectinib) Information

Drug Name | Vitrakvi (larotrectinib)
Study Cohort | Oncology
Label Indications | VITRAKVI is a kinase inhibitor indicated for the treatment of adult and pediatric patients with solid tumors that: have a neurotrophic receptor tyrosine kinase (NTRK) gene fusion without a known acquired resistance mutation, are metastatic or where surgical resection is likely to result in severe morbidity and have no satisfactory alternative treatments or that have progressed following treatment. Select patients for therapy based on an FDA-approved test. This indication is approved under accelerated approval based on overall response rate and duration of response. Continued approval for this indication may be contingent upon verification and description of clinical benefit in confirmatory trials.
Original Company | Loxo Oncology, Inc.
Current Company | Bayer
FDA Approval Date | November 2018
FDA Submission Classification | Type 1 - New Molecular Entity
Type | Small molecule
Preclinical Information | Duration (in Months) | | 64.1
Clinical Information | Phase 1 | Number of Studies | 1
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 75
Clinical Information | Phase 1 | Total Phase Duration (in Months) | 32.9
Clinical Information | Phase 2 | Number of Studies | 1
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 174
Clinical Information | Phase 2 | Total Phase Duration (in Months) | 9.2
Clinical Information | Phase 3 | Number of Studies | 0
Clinical Information | Phase 3 | Total Enrollment (All Studies) | NA
Clinical Information | Phase 3 | Total Phase Duration (in Months) | NA
FDA Review Information | Duration (in Months) | | 8.1
Post-approval Information | Phase 4 | Number of Studies | 0
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | NA
Route of Administration | Oral | | Rank = 1
QIDP Designation (Yes/No) | NA | | NA
BARDA Funding (Yes/No) | NA | | NA
Type of FDA Review | Priority; Orphan
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | No | | Rank = 5
Activity Against ESKAPE Pathogens (Yes/No) [a] | NA | | NA
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | NA | | NA
Approximate Annual Number U.S. Cases | NA | | Rank = 13
Estimated Inpatient Market Size [k] | NA | | NA
Number of Drugs Available for Indication(s) in the U.S. | NA | | Rank = 14
Trinity Drug Index | Therapeutic Score [d] | NA | Rank = 7
Trinity Drug Index | Commercial Score [e] | NA | Rank = 7
Trinity Drug Index | R&D Score [f] | NA | Rank = 7
Trinity Drug Index | Overall Score [g] | NA | Rank = 7
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | NA | Rank = 12
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | NA | Rank = 12
British Health Assessment (NICE) * | NA | | Rank = 14
German Dossier Assessment (IQWiG) | Added benefit not proven | | Rank = 8
AST Device Incorporation | Vitek^®^ 2 | NA | NA
AST Device Incorporation | MicroScan | NA | NA
ICER Assessment * | NA | | Rank = 4
IDSA Guideline Inclusion | NA | | NA
P&T Community Decision * | NA | | Rank = 4
Medicaid Coverage | CA | PPA | Rank = 2
Medicaid Coverage | NY | Y | Rank = 2
Medicaid Coverage | TX | OT | Rank = 2
Medicaid Coverage | PA | Y | Rank = 2
Medicaid Coverage | FL | NPA | Rank = 2
Medicaid Coverage | OH | PA | Rank = 2
Medicaid Coverage | IL | NPA | Rank = 2
Medicaid Coverage | MA | PPA | Rank = 2
Medicaid Coverage | MI | Y | Rank = 2
Medicaid Coverage | NJ | Y | Rank = 2
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $31.7
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $782.1
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 282.3
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 152.0
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $60.67

Table A - 29 Rubraca (rucaparib) Information

Drug Name | Rubraca (rucaparib)
Study Cohort | Oncology
Label Indications | RUBRACA is a poly (ADP-ribose) polymerase (PARP) inhibitor indicated: for the maintenance treatment of adult patients with recurrent epithelial ovarian, fallopian tube, or primary peritoneal cancer who are in a complete or partial response to platinum-based chemotherapy; for the treatment of adult patients with a deleterious BRCA mutation (germline and/or somatic)-associated epithelial ovarian, fallopian tube, or primary peritoneal cancer who have been treated with two or more chemotherapies. Select patients for therapy based on an FDA-approved companion diagnostic for RUBRACA. It is also indicated for the treatment of adult patients with a deleterious BRCA mutation (germline and/ or somatic)-associated metastatic castration-resistant prostate cancer (mCRPC) who have been treated with androgen receptor-directed therapy and a taxane-based chemotherapy. Select patients for therapy based on an FDA-approved companion diagnostic for RUBRACA. This indication is approved under accelerated approval based on objective response rate and duration of response. Continued approval for this indication may be contingent upon verification and description of clinical benefit in confirmatory trials.
Original Company | Clovis Oncology
Current Company | Clovis Oncology
FDA Approval Date | December 2016
FDA Submission Classification | Type 1 - New Molecular Entity
Type | Small molecule
Preclinical Information | Duration (in Months) | | 127.2
Clinical Information | Phase 1 | Number of Studies | 1
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 85
Clinical Information | Phase 1 | Total Phase Duration (in Months) | 49.9
Clinical Information | Phase 2 | Number of Studies | 2
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 97
Clinical Information | Phase 2 | Total Phase Duration (in Months) | 99.8
Clinical Information | Phase 3 | Number of Studies | 1
Clinical Information | Phase 3 | Total Enrollment (All Studies) | 564
Clinical Information | Phase 3 | Total Phase Duration (in Months) | 38.9
FDA Review Information | Duration (in Months) | | 5.9
Post-approval Information | Phase 4 | Number of Studies | 0
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | NA
Route of Administration | Oral | | Rank = 1
QIDP Designation (Yes/No) | NA | | NA
BARDA Funding (Yes/No) | NA | | NA
Type of FDA Review | Priority; Orphan
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | Yes | | Rank = 1
Activity Against ESKAPE Pathogens (Yes/No) [a] | NA | | NA
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | NA | | NA
Approximate Annual Number U.S. Cases | 22,530 | | Rank = 11
Estimated Inpatient Market Size [k] | NA | | NA
Number of Drugs Available for Indication(s) in the U.S. | 22 | | Rank = 7
Trinity Drug Index | Therapeutic Score [d] | 3 | Rank = 6
Trinity Drug Index | Commercial Score [e] | 2.2 | Rank = 4
Trinity Drug Index | R&D Score [f] | 4.5 | Rank = 1
Trinity Drug Index | Overall Score [g] | 3 | Rank = 4
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | Substantial | Rank = 1
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | Moderate (III) | Rank = 1
British Health Assessment (NICE) * | Recommended | | Rank = 1
German Dossier Assessment (IQWiG) | Added benefit not proven | | Rank = 8
AST Device Incorporation | Vitek^®^ 2 | NA | NA
AST Device Incorporation | MicroScan | NA | NA
ICER Assessment * | C+; P/ would need to be discounted / Promising but inconclusive evidence | | Rank = 2
IDSA Guideline Inclusion | NA | | NA
P&T Community Decision * | NA | | Rank = 4
Medicaid Coverage | CA | PA | Rank = 2
Medicaid Coverage | NY | Y | Rank = 2
Medicaid Coverage | TX | Y; OT | Rank = 2
Medicaid Coverage | PA | PPA | Rank = 2
Medicaid Coverage | FL | Y; QL | Rank = 2
Medicaid Coverage | OH | PA | Rank = 2
Medicaid Coverage | IL | NPA | Rank = 2
Medicaid Coverage | MA | PPA | Rank = 2
Medicaid Coverage | MI | Y | Rank = 2
Medicaid Coverage | NJ | Y | Rank = 2
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $70.7
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $3,246.3
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 124.3
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 95.6
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $18.21

Table A - 30 Jevtana (cabazitaxel) Information

Drug Name | Jevtana (cabazitaxel)
Study Cohort | Oncology
Label Indications | JEVTANA is a microtubule inhibitor indicated in combination with prednisone for treatment of patients with metastatic castration-resistant prostate cancer previously treated with a docetaxel-containing treatment regimen.
Original Company | sanofi-aventis U.S., LLC
Current Company | sanofi-aventis U.S., LLC
FDA Approval Date | June 2010
FDA Submission Classification | Type 1 - New Molecular Entity
Type | Small molecule
Preclinical Information | Duration (in Months) | | 93.0
Clinical Information | Phase 1 | Number of Studies | 4
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 92
Clinical Information | Phase 1 | Total Phase Duration (in Months) | 33.9
Clinical Information | Phase 2 | Number of Studies | 2
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 104
Clinical Information | Phase 2 | Total Phase Duration (in Months) | NA
Clinical Information | Phase 3 | Number of Studies | 1
Clinical Information | Phase 3 | Total Enrollment (All Studies) | 755
Clinical Information | Phase 3 | Total Phase Duration (in Months) | 31.9
FDA Review Information | Duration (in Months) | | 2.6
Post-approval Information | Phase 4 | Number of Studies | 4
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | 400
Route of Administration | Intravenous | | Rank = 9
QIDP Designation (Yes/No) | NA | | NA
BARDA Funding (Yes/No) | NA | | NA
Type of FDA Review | Priority
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | No | | Rank = 5
Activity Against ESKAPE Pathogens (Yes/No) [a] | NA | | NA
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | NA | | NA
Approximate Annual Number U.S. Cases | 174,650 | | Rank = 6
Estimated Inpatient Market Size [k] | NA | | NA
Number of Drugs Available for Indication(s) in the U.S. | 23 | | Rank = 8
Trinity Drug Index | Therapeutic Score [d] | NA | Rank = 7
Trinity Drug Index | Commercial Score [e] | NA | Rank = 7
Trinity Drug Index | R&D Score [f] | NA | Rank = 7
Trinity Drug Index | Overall Score [g] | NA | Rank = 7
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | Substantial | Rank = 1
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | Minor (IV) | Rank = 4
British Health Assessment (NICE) * | Recommended in combination with prednisone or prednisolone | | Rank = 1
German Dossier Assessment (IQWiG) | Considerable added benefit over 65yo, not quantifiable added benedit under 65yo | | Rank = 1
AST Device Incorporation | Vitek® 2 | NA | NA
AST Device Incorporation | MicroScan | NA | NA
ICER Assessment * | NA | | Rank = 4
IDSA Guideline Inclusion | NA | | NA
P&T Community Decision * | Effective second-line agent | | Rank = 2
Medicaid Coverage | CA | P | Rank = 11
Medicaid Coverage | NY | MB; OT | Rank = 11
Medicaid Coverage | TX | Y | Rank = 11
Medicaid Coverage | PA | Y | Rank = 11
Medicaid Coverage | FL | NPA | Rank = 11
Medicaid Coverage | OH | MB; OT | Rank = 11
Medicaid Coverage | IL | Y | Rank = 11
Medicaid Coverage | MA | PPA | Rank = 11
Medicaid Coverage | MI | N | Rank = 11
Medicaid Coverage | NJ | P | Rank = 11
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $77.8
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $2,517.8
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 180.7
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 163.7
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $496.25

Table A - 31 Yondelis (trabectedin) Information

Drug Name | Yondelis (trabectedin)
Study Cohort | Oncology
Label Indications | YONDELIS is an alkylating drug indicated for the treatment of patients with unresectable or metastatic liposarcoma or leiomyosarcoma who received a prior anthracycline-containing regimen.
Original Company | Janssen Products, L.P.
Current Company | Janssen Products, L.P.
FDA Approval Date | October 2015
FDA Submission Classification | Type 1 - New Molecular Entity
Type | Small molecule
Preclinical Information | Duration (in Months) | | 49.7
Clinical Information | Phase 1 | Number of Studies | 6
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 126
Clinical Information | Phase 1 | Total Phase Duration (in Months) | 225.6
Clinical Information | Phase 2 | Number of Studies | 18
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 1370
Clinical Information | Phase 2 | Total Phase Duration (in Months) | 173.6
Clinical Information | Phase 3 | Number of Studies | 7
Clinical Information | Phase 3 | Total Enrollment (All Studies) | 3,107
Clinical Information | Phase 3 | Total Phase Duration (in Months) | 188.7
FDA Review Information | Duration (in Months) | | 10.9
Post-approval Information | Phase 4 | Number of Studies | 0
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | NA
Route of Administration | Intravenous | | Rank = 9
QIDP Designation (Yes/No) | NA | | NA
BARDA Funding (Yes/No) | NA | | NA
Type of FDA Review | Priority; Orphan
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | Yes | | Rank = 1
Activity Against ESKAPE Pathogens (Yes/No) [a] | NA | | NA
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | NA | | NA
Approximate Annual Number U.S. Cases | NA | | Rank = 13
Estimated Inpatient Market Size [k] | NA | | NA
Number of Drugs Available for Indication(s) in the U.S. | 2 | | Rank = 1
Trinity Drug Index | Therapeutic Score [d] | 3.2 | Rank = 4
Trinity Drug Index | Commercial Score [e] | 1.8 | Rank = 5
Trinity Drug Index | R&D Score [f] | 1.5 | Rank = 6
Trinity Drug Index | Overall Score [g] | 2.3 | Rank = 5
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | Substantial | Rank = 1
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | Minor (IV) | Rank = 4
British Health Assessment (NICE) * | Recommended | | Rank = 1
German Dossier Assessment (IQWiG) | NA | | Rank = 13
AST Device Incorporation | Vitek^®^ 2 | NA | NA
AST Device Incorporation | MicroScan | NA | NA
ICER Assessment * | NA | | Rank = 4
IDSA Guideline Inclusion | NA | | NA
P&T Community Decision * | NA | | Rank = 4
Medicaid Coverage | CA | P | Rank = 11
Medicaid Coverage | NY | MB; OT | Rank = 11
Medicaid Coverage | TX | Y | Rank = 11
Medicaid Coverage | PA | Y | Rank = 11
Medicaid Coverage | FL | NPA | Rank = 11
Medicaid Coverage | OH | PA | Rank = 11
Medicaid Coverage | IL | Y | Rank = 11
Medicaid Coverage | MA | PA | Rank = 11
Medicaid Coverage | MI | N | Rank = 11
Medicaid Coverage | NJ | P | Rank = 11
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $395.5
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $29,710.7
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 198.2
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 147.4
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $69.09

Table A - 32 Cometriq (cabozantinib) Information

Drug Name | Cometriq (cabozantinib)
Study Cohort | Oncology
Label Indications | COMETRIQ is a kinase inhibitor indicated for the treatment of patients with progressive, metastatic medullary thyroid cancer (MTC).
Original Company | Exelixis, Inc.
Current Company | Exelixis, Inc.
FDA Approval Date | November 2012
FDA Submission Classification | Type 1 - New Molecular Entity
Type | Small molecule
Preclinical Information | Duration (in Months) | | 21.1
Clinical Information | Phase 1 | Number of Studies | 8
Clinical Information | Phase 1 | Total Enrollment (All Studies) | 291
Clinical Information | Phase 1 | Total Phase Duration (in Months) | 82.9
Clinical Information | Phase 2 | Number of Studies | 2
Clinical Information | Phase 2 | Total Enrollment (All Studies) | 241
Clinical Information | Phase 2 | Total Phase Duration (in Months) | 48.9
Clinical Information | Phase 3 | Number of Studies | 1
Clinical Information | Phase 3 | Total Enrollment (All Studies) | 330
Clinical Information | Phase 3 | Total Phase Duration (in Months) | 39.9
FDA Review Information | Duration (in Months) | | 6.3
Post-approval Information | Phase 4 | Number of Studies | 2
Post-approval Information | Phase 4 | Total Enrollment (All Studies) | 358
Route of Administration | Oral | | Rank = 1
QIDP Designation (Yes/No) | NA | | NA
BARDA Funding (Yes/No) | NA | | NA
Type of FDA Review | Priority; Orphan
New Molecular Entity (Yes/No) | Yes | | Rank = 1
New Chemical Entity (Yes/No) | No | | Rank = 5
Activity Against ESKAPE Pathogens (Yes/No) [a] | NA | | NA
Activity Against CDC Urgent or WHO Critical Threat Pathogens (Yes/No) [b][c] | NA | | NA
Approximate Annual Number U.S. Cases | 1,000 | | Rank = 12
Estimated Inpatient Market Size [k] | NA | | NA
Number of Drugs Available for Indication(s) in the U.S. | 2 | | Rank = 1
Trinity Drug Index | Therapeutic Score [d] | NA | Rank = 7
Trinity Drug Index | Commercial Score [e] | NA | Rank = 7
Trinity Drug Index | R&D Score [f] | NA | Rank = 7
Trinity Drug Index | Overall Score [g] | NA | Rank = 7
French Health Assessment (Haute Autorité de Santé) | Actual Benefit [i] | NA | Rank = 12
French Health Assessment (Haute Autorité de Santé) | Clinical Added Value [j] | NA | Rank = 12
British Health Assessment (NICE) * | Recommended | | Rank = 1
German Dossier Assessment (IQWiG) | Non-quantifiable added benefit | | Rank = 6
AST Device Incorporation | Vitek^®^ 2 | NA | NA
AST Device Incorporation | MicroScan | NA | NA
ICER Assessment * | NA | | Rank = 4
IDSA Guideline Inclusion | NA | | NA
P&T Community Decision * | NA | | Rank = 4
Medicaid Coverage | CA | P | Rank = 2
Medicaid Coverage | NY | Y | Rank = 2
Medicaid Coverage | TX | Y; OT | Rank = 2
Medicaid Coverage | PA | PPA | Rank = 2
Medicaid Coverage | FL | NPA | Rank = 2
Medicaid Coverage | OH | PA | Rank = 2
Medicaid Coverage | IL | NPA | Rank = 2
Medicaid Coverage | MA | PPA | Rank = 2
Medicaid Coverage | MI | Y | Rank = 2
Medicaid Coverage | NJ | Y | Rank = 2
Estimated Development and Approval Cost | Cost (in $ Million 2018) | | $97.5
Estimated Development and Approval Cost | Expected Capitalized Cost (in $ Million 2018) | | $2,604.4
Overall Clinical Value Score | With European Health Technology Assessment (HTA) Scores | | 209.8
Overall Clinical Value Score | Without European Health Technology Assessment (HTA) Scores | | 124.0
First 9 Quarters IQVIA MIDAS Sales (in $ Million 2018) | $59.38