# LIST OF ACRONYMS

AACT: Access to Aggregate Content of ClinicalTrials.gov
AB: Actual benefit
ABSSSI: Acute bacterial skin and skin structure infection
ACB: Actual clinical benefit
AM: Antimicrobial
ASPR: Office of the Assistant Secretary for Preparedness and Response
AST: Antimicrobial susceptibility test
BARDA: HHS Biomedical Advanced Research and Development Authority
BL-BLI: Beta-lactam/beta-lactamase inhibitor
BLA: Biologics license application
CABP: Community-acquired bacterial pneumonia
CAPM: Capital asset pricing model
CAV: Clinical added value
CBER: FDA’s Center for Biologics Evaluation and Research
CDC: Centers for Disease Control and Prevention
CDER: FDA’s Center for Drug Evaluation and Research
CDI: Clostridioides difficile (aka C. difficile) infection
CIAI: Complicated intra-abdominal infection
CMC: Chemistry, manufacturing, and controls
COPD: Chronic obstructive pulmonary disease
CPP: Cost per patient
CRE: Carbapenem-resistant Enterobacterales
CRO: Contract research organization
CTTI: Clinical Trials Transformation Initiative
CUTI: Complicated urinary tract infection
DRG: Diagnosis-related group
ERG: Eastern Research Group, Inc.
ESKAPE: Enterococcus faecium, Staphylococcus aureus, Klebsiella pneumoniae, Acinetobacter baumannii, Pseudomonas aeruginosa, and Enterobacter species
FDA: U.S. Food and Drug Administration
FPDS-NG: Federal Procurement Data System (FPDS) – Next Generation
GAIN: Generating Antibiotic Incentives Now Act of 2012
HABP/VABP: Hospital-acquired bacterial pneumonia / ventilator-associated bacterial pneumonia
HAS: Haute Autorité de Santé
HTA: Health technology assessment
ICER: Institute for Clinical and Economic Review
IDSA: Infectious Diseases Society of America
INAHTA: International Network of Agencies for Health Technology Assessment
IND: Investigational new drug
IQWiG: Institute for Quality and Efficiency in Health Care
ISPOR: International Society for Pharmacoeconomics and Outcomes Research
IV: Intravenous
MCDA: Multicriteria decision analysis
MDR: Multidrug resistant
NCE: New chemical entity
NDA: New drug application
NIAID: National Institute of Allergy and Infectious Disease
NICE: U.K. National Institute for Health and Care Excellence
NIH: National Institutes of Health
NME: New molecular entity
OCOC: Opportunity cost of capital
PAG: Project advisory group
P&T: Pharmacy & Therapeutics
PHS: U.S. Public Health Service
PIDD: Primary immune deficiency disease
PDP: Product development partnership
R&D: Research and development
RE: Relative effectiveness
QIDP: Qualified infectious disease product
USPTO: United States Patent and Trademark Office
WHO: World Health Organization