# 5 REFERENCES

1928, Undated. Impact Infection Control for Quality Care Providers. [Online] Available at: https://www.1928diagnostics.com/ [Accessed 1 October 2022].
Aagaard H., Malpani R. & Zorzet A., 2021. Ensuring sustainable access to effective antibiotics for everyone - everywhere, s.l.: ReAct.
Abat C. , 2018. Extremely and pandrug-resistant bacteria extra-deaths: myth or reality?. European Journal of Clinical Microbiology & Infectious Diseases, pp. 1687–1697.29956024
AMR Action Fund, 2022. AMR Action Fund Announces First Investments in Adaptive Phage Therapeutics and Venatorx Pharmaceuticals. [Online].
AMR Action Fund, 2022. Enabling Breakthroughs in Antimicrobials. [Online] Available at: https://www.amractionfund.com/ [Accessed 6 December 2022].
Anon., 2022. ContraFect Product Candidates. [Online] Available at: https://www.contrafect.com/pipeline/overview
Bækkeskov E., 2019. Market Failure. Encyclopedia Britannica, 1 October, pp. https://www.britannica.com/topic/market-failure.
Bergin S. P. , 2015. Neonatal Escherichia coli Bloodstream Infections: Clinical Outcomes and Impact of Initial Antibiotic Therapy. Pediatric Infectious Disease, 34(9), pp. 933–936.
Biehle L. R. , 2015. Outcomes and Risk Factors for Mortality among Patients Treated with Carbapenems for Klebsiella spp. Bacteremia. PLoS One, 10(11), pp. 6–13.
Biomarin Pharmaceuticals, 2022. BioMarin Sells Priority Review Voucher for $110 Million. [Online] Available at: https://investors.biomarin.com/2022-02-09-BioMarin-Sells-Priority-Review-Voucher-for-110-Million
Blankenship K., 2020. As U.S. calls for stateside manufacturing, antibiotic maker Paratek gambles on 'onshoring' effort. [Online] Available at: https://www.fiercepharma.com/manufacturing/as-u-s-calls-for-stateside-manufacturing-antibiotic-maker-paratek-gambles-onshoring
Blaskovich M. A., Butler M. S. & Cooper M. A., 2017. Polishing the tarnished silver bullet: the quest for new antibiotics. Essays in Biochemistry, pp. 103–114.28258234
Branch-Elliman W. , 2012. Risk factors for Staphylococcus aureus postpartum breast abscess. Clinical Infectious Diseases, 54(1), pp. 71–77.22052894
Cama J. , 2021. To Push or To Pull? In a Post-COVID World, Supporting and Incentivizing Antimicrobial Drug Development Must Become a Governmental Priority. ACS Infectious Diseases, pp. 2029–2042.33606496
Castón J. J. , 2014. High vancomycin minimum inhibitory concentration is associated with poor outcome in patients with methicillin-susceptible Staphylococcus aureus bacteremia regardless of treatment. Scandinivian Journal of Infectious Diseases, 46(11), pp. 783–786.
CDC, 2013. Antibiotic Resistance Threats in the United States, s.l.: Center for Disease Control and Prevention.
CDC, 2021. How Antibiotic Resistance Happens. [Online] Available at: https://www.cdc.gov/drugresistance/about/how-resistance-happens.html
CDC, 2022. COVID-19: U.S. Impact on Antimicrobial Resistance, Special Report 2022, Atlanta: U.S. Department of Health and Human Services, CDC.
Cernuschi T. , 2011. Advance market commitment for pneumococcal vaccines: putting theory into practice. Bulletin of the World Health Organization, 89(12), pp. 913–918.22271949
Chapman R., 2020. Why is it so hard to develop new antibiotics?. [Online] Available at: https://wellcome.org/news/why-is-it-so-hard-develop-new-antibiotics
Chopra T. , 2013. Epidemiology of Bloodstream Infections Caused by Acinetobacter baumannii and Impact of Drug Resistance to both Carbapenems and Ampicillin-Sulbactam on Clinical Outcomes. Antimicrobial Agents Chemotherapy, 57(12), pp. 6270–6275.24100492
Coates A., 2019. Are new antibiotic combinations the solution to the AMR crisis? – by Anthony Coates. [Online] Available at: https://revive.gardp.org/are-new-antibiotic-combinations-the-solution-to-the-amr-crisis/
Dall C., 2021. WHO report highlights shortage of new antibiotics. [Online] Available at: https://www.cidrap.umn.edu/news-perspective/2021/04/who-report-highlights-shortage-new-antibiotics
Dall C., 2022. UK moves closer to experimental payment model for antibiotics. [Online] Available at: https://www.cidrap.umn.edu/news-perspective/2022/04/uk-moves-closer-experimental-payment-model-antibiotics
D'Andrea M. M., Fraziano M., Thaller M. C. & Rossolini G. M., 2019. The Urgent Need for Novel Antimicrobial Agents and Strategies to Fight Antibiotic Resistance. Antibiotics (Basel), p. 254.31817707
Daniel G., Scheider M., Lopez M. H. & McClellan M., 2018. Implementation of a Market Entry Reward within the United States. The Journal of Law, Medicine and Ethics, 46(1), pp. 50–58.
Deak D., Outterson K., Powers J. H. & Kesselheim A. S., 2016. Progress in the Fight Against Multidrug-Resistant Bacteria? A Review of U.S. Food and Drug Administration–Approved Antibiotics, 2010–2015. Annals of Internal Medicine, pp. 1–15.
Diallo O. O. e. a., 2020. Major discrepancy between factual antibiotic resistance and consumption in South of France: analysis of 539,037 bacterial strains. Nature Research, pp. 1–9.
Dutescu I. & Hillier S., 2021. Encouraging the Development of New Antibiotics: Are Financial Incentives the Right Way Forward? A Systematic Review and Case Study. Infection and Drug Resistance, Volume 14, pp. 415–434. doi: 10.2147/IDR.S287792.33574682
Eastern Research Group, Inc., 2018. Expert Interviews for Incentives to Develop Antibacterial Drugs, s.l.: Unpublished.
Ericson J. , 2015. Burden of Invasive Staphylococcus aureus Infections in Hospitalized Infants. Journal of the American Medical Association Pediatrics, Volume 1105, p. 169.
Ershova J. V., Kurbatova E. V., PK M. & Cegielski J., 2014. Mortality Among Tuberculosis Patients With Acquired Resistance to Second-line Antituberculosis Drugs--United States, 1993–2008. Clinical Infectious Diseases, Volume 59, pp. 465–72.24846639
Espacenet, 2022. Espacenet Patent Search. [Online] Available at: https://www.epo.org/searching-for-patents/technical/espacenet.html [Accessed 18 August 2022].
Farmakiotis D., Kyvernitakis A., Tarrand J. & Kontoyiannis D., 2015. Early initiation of appropriate treatment is associated with increased survival in cancer patients with Candida glabrata fungaemia: A potential benefit from infectious disease consultation. Clinical Microbiology and Infection, Volume 21, p. 79–86.25636931
FDA, 2022. FDA Drug Shortages. [Online] Available at: https://www.accessdata.fda.gov/scripts/drugshortages/default.cfm [Accessed 1 October 2022].
Fitzpatrick M., Ozer E., Bolon M. & Hauser A., 2015. Influence of ACB complex genospecies on clinical outcomes in a U.S. hospital with high rates of multidrug resistance. Journal of Infection, Volume 70, pp. 144–52.25246361
Ford C. , 2015b. The clinical impact of vancomycin-resistant Enterococcus colonization and bloodstream infection in patients undergoing autologous transplantation. Transplant infectious disease: an official journal of the Transplantation Society, Volume 17, p. 688–94.26256692
Ford C. , 2015a. Frequency, risk factors, and outcomes of vancomycin-resistant Enterococcus colonization and infection in patients with newly diagnosed acute leukemia: different patterns in patients with acute myelogenous and acute lymphoblastic leukemia. Infection control and hospital epidemiology, Volume 36, pp. 47–53.25627761
Gibson R., 2021. MarketWatch. [Online] Available at: https://www.marketwatch.com/story/china-has-cornered-the-market-on-antibiotics-so-the-u-s-must-rebuild-its-manufacturing-capacity-11619640612 [Accessed 1 October 2022].
Guerrini C., 2014. Defining Patent Quality. Fordham Law Review, 82(6).
Hattemer A. , 2013. Bacterial and clinical characteristics of health care-and community-acquired bloodstream infections due to pseudomonas aeruginosa. Antimicrobial Agents and Chemotherapy, Volume 57, p. 3969–75.23733476
Hill D. , 2013. Methicillin-Resistant Staphylococcus aureus in Early Ventilator-Associated Pneumonia: Cause for Concern?. Surgical Infections, Volume 14, pp. 520–4.24116739
Hutchings M. I., Truman A. W. & Wilkinson B., 2019. Antibiotics: past, present and future. Current Opinions in Microbiology, pp. 72–80.
Hyun D., 2022. Major Layoffs Underscore Continuing Struggle to Develop New Antibiotics. [Online].
Jernigan J. A. e. a., 2020. Multidrug-Resistant Bacterial Infections in U.S. Hospitalized Patients, 2012–2017. The New England Journal of Medicine, pp. 1309–1319.32242356
Johnson K., Thorpe K. E., Jacob J. T. & Murphy D. J., 2019. The incremental cost of infections associated with multidrug-resistant organisms in the inpatient hospital setting—A national estimate. Health Service Research, 54(4), pp. 782–792.
Khanna N., 2019. Patent Quality: Does One Size Fit All?, Brussels, Belgium: 4iP Counsel.
Kim D. , 2014. Cardiac implanted electronic device-related infective endocarditis: Clinical features, management, and outcomes of 80 consecutive patients. PACE - Pacing and Clinical Electrophysiology, Volume 37, p. 978–85.25060820
Kitazono H., Rog D., Sa G. & Nm C., 2015. Acinetobacter RGE. Acinetobacter baumannii infection in solid organ transplant recipients. Clinical Transplantation, p. 227–32.25580999
Klug D. , 2021. There is No Market for New Antibiotics: This Allows an Open Approach to Research and Development. Wellcome Open Research, 6(146), p. 10.12688/wellcomeopenres.16847.1.
Krueger A. , 2014. Clinical Outcomes of Nalidixic Acid, Ceftriaxone, and Multidrug-Resistant Nontyphoidal Salmonella Infections Compared with Pansusceptible Infections in FoodNet Sites, 2006–2008. Foodborne Pathogens and Disease, Volume 11, p. 335–41.24617446
Lee B. , 2013. The economic burden of community-associated methicillin-resistant Staphylococcus aureus (CA-MRSA). Clinical Microbiology and Infection, Volume 19, p. 528–36.22712729
MacVane S., Tuttle L. & Nicolau D., 2014. Impact of extended-spectrum β-lactamase-producing organisms on clinical and economic outcomes in patients with urinary tract infection. Journal of Hospital Medicine, Volume 9, p. 232–8.24464783
Manandhar S. , 2016. Does Staphylococcus aureus Bacteriuria Predict Clinical Outcomes in Patients With Bacteremia? Analysis of 274 Patients With Staphylococcus aureus Blood Stream Infection. Infectious Diseases in Clinical Practice, Volume 24, pp. 151–54.
Marchant J., 2020. Powerful antibiotics discovered using AI. Nature.
Martinez O. F., Cardoso M. H., Ribeiro S. M. & Franco O.-L., 2019. Therapeutic Strategies With a Focus on Dismantling Bacterial Membrane Microdomains, Toxin Neutralization, Quorum-Sensing Interference and Biofilm Inhibition. Frontier in Cellular and Infection Microbiology, 2 April .
Martin G., 2015. Newly Discoverd Antibiotic Kills. [Online] Available at: https://news.northeastern.edu/2015/01/07/kim-lewis-teixobactin-nature-paper/
McCarthy N., 2021. Which Companies Received The Most Covid-19 Vaccine R&D Funding?. [Online] Available at: https://www.forbes.com/sites/niallmccarthy/2021/05/06/which-companies-received-the-most-covid-19-vaccine-rd-funding-infographic/?sh=ed494cf4333d
McDonnell A., 2016. Clinical Trial Networks for Antibiotic Development: Why They Are Important and How They Should Be Developed. [Online] Available at: https://wellcome.org/sites/default/files/clinical-trial-networks-for-antibiotic-development-wellcome-oct16.pdf
Megget K., 2018. Novartis exit from antibiotics a setback for race against resistance. Chemistry World, 30 July .
Meyer R. J., 2021. Priority Review Vouchers: GAO Report Provides Scant Evidence of Success. Clinical and Translational Science, 14 January, pp. 8–10.32949480
Miles-Jay A., Butler-Wu S., Rowhani-Rahbar A. & Pergam S., 2015. Incidence rate of fluoroquinolone resistant gram-negative rod bacteremia among allogeneic hematopoietic cell transplant patients during an era of levofloxacin prophylaxis.. Biology of Blood Marrow Transplant, Volume 257, pp. 539–545.
Minssen T. , 2020. Social, cultural and economic aspects of antimicrobial resistance. Bulletin of the World Health Organization, p. 823.33293739
Mohajer M. A. & Musher D. M. M. C. G. D. R. O., 2013. Clinical significance of Staphylococcus aureus bacteriuria at a tertiary care hospital. Scandinavian Journal of Infectious Diseases, 45(9), pp. 688–695.23808717
Moran D., 2019. A framework for improved one health. BMJ Global Health, Volume 4, pp. 1–6.
Mossialos E. , 2010. Policies and Incentives for Promoting Innovation in Antibiotic Research, London, United Kingdom: World Health Organization on behalf of the European Observatory on Health Systems and Policies.
Nathan C., 2020. Commentary: Stemming the Tide of Resistant Infections is Tough but Not Intractable. [Online] Available at: https://news.weill.cornell.edu/news/2020/04/commentary-stemming-the-tide-of-resistant-infections-is-tough-but-not-intractable [Accessed 15 June 2022].
National Academies of Sciences, Engineering and Medicine, 2022. Combating Antimicrobial Resistance and Protecting the Miracle of Modern Medicine, Washington, DC: The National Academies Press.
National Academies of Sciences, Engineering, and Medicine, 2022. Combating Antimicrobial Resistance and Protecting the Miracle of Modern Medicine., Washington, DC:: The National Academies Press.
Naylor N. , 2018. Estimating the Burden of Antimicrobial Resistance: a Systematic Literature Review. Antimicrobial Resistance & Infection Control, 7(58), pp. 10.1186/s13756-018-0336-y.
Nelson R. , 2015b. The Impact of Healthcare-Associated Methicillin-Resistant Staphylococcus Aureus Infections on Post-Discharge Healthcare Costs and Utilization. Infection Control & Hospital Epidemiology, Volume 9, p. 534–542.
Nelson R. , 2015a. Reducing Time-dependent Bias in Estimates of the Attributable Cost of Health Care-associated Methicillin-resistant Staphylococcus aureus Infections: A Comparison of Three Estimation Strategies. Medical Care, Volume 53, pp. 827–834.26225444
Nelson R., Stevens V., Jones M. & Samore M. R. M., 2015c. Health care associated methicillin-resistant Staphylococcus aureus infections increases the risk of postdischarge mortality. American Journal of Infection Control, Volume 43, pp. 28–43.
Ny P., Nieberg P. & Wong-Beringer A., 2014. Impact of carbapenem resistance on epidemiology and outcomes of nonbacteremic Klebsiella pneumoniae infections. Washington, DC, Elsevier, Inc..
O'Brien M. & Chu P., 2020. A Market Failure for Antimicrobial Resistant Medicines. Applied Clinical Trials Online.
Okhravi C. , 2018. Simulating Market Entry Rewards for Antibiotics Development. The Journal of Law and Ethics, pp. 32–42.
Ong J. , 2022. Accelerating 3D Printing of Pharmaceutical Products Using Machine Learning. International Journal of Pharmaceutics: X, 9(4), p. 100120. doi: 10.1016/j.ijpx.2022.100120.
Park J. , 2019. Systematic Review of Basket Trials, Umbrella Trials, and Platform Trials: A Landscape Analysis of Master Protocols. Trials, 20(572), pp. 10.1186/s13063-019-3664-1.
Patel S. , 2014. Risk factors and outcomes of infections caused by extremely drug-resistant gram-negative bacilli in patients hospitalized in intensive care units. American Journal of Infection Control, Volume 42, pp. 626–631.24725516
Patel T. & Nagel N., 2015. Clinical outcomes of enterobacteriaceae infections stratified by carbapenem MICs. Journal of Clinical Microbiology, Volume 53, pp. 201–5.25378572
Payne D. , 2015. Time for a change: addressing R&D and commercialization challenges for antibacterials. Philosophical Transactions of the Royal Society B, p. June 5.
Pereira M. , 2015. Risk factors and outcomes of carbapenem-resistant Klebsiella pneumoniae infections in liver transplant recipients. Liver Transplantation, Volume 21, p. 1511–9.26136397
Pew Trusts, 2021. Tracking the Global Pipeline of Antibiotics in Development, March 2021. [Online] Available at: https://www.pewtrusts.org/en/research-and-analysis/issue-briefs/2021/03/tracking-the-global-pipeline-of-antibiotics-in-development [Accessed 28 September 2022].
Pew, 2018. ‘Gram-Negative Bacteria Pose a Significant Scientific Challenge’. [Online] Available at: https://www.pewtrusts.org/en/research-and-analysis/articles/2018/06/20/gram-negative-bacteria-pose-a-significant-scientific-challenge#:~:text=Gram%2Dnegative%20bacteria%2C%20such%20as,for%20antibiotics%20to%20work%20effectively
Pezzani M. D. , 2021. Methodological quality of studies evaluating the burden of drug-resistant infections in humans due to the WHO Global Antimicrobial Resistance Surveillance System target bacteria. Clinical Microbiology and Infection, pp. 687–696.33450389
Powers J. H., Evans S. R. & Kesselheim A. S., 2018. Studying new antibiotics for multidrug resistant infections: are today’s patients paying for unproved future benefits?. BMJ, pp. 1–6.
Principi N., Silvestri E. & Esposito S., 2019. Advantages and Limitations of Bacteriophages for the Treatment of Bacterial Infections. Frontiers in Pharmacology, 8 May.
Qureshi Z. , 2014. Epidemiology and clinical outcomes of patients with carbapenem-resistant Klebsiella pneumoniae bacteriuria. Antimicrobial agents and chemotherapy, Volume 58, pp. 1–18.24100489
Rattinger G., Jain R., Ju J. & Mullins C., 2008. Principles of Economics Crucial to Pharmacy Students' Understanding of the Prescription Drug Market. American Journal of Pharmaceutical Education, 72(3), p. 61. doi: 10.5688/aj720361.18698403
Renwick M. & Mossialos E., 2018. What are the economic barriers of antibiotic R&D and how can we overcome them. Expert Opinion on Drug Discovery, pp. 889–892.30175625
Rex J., 2019. AMR.Solutions. [Online] Available at: https://amr.solutions/2019/08/04/new-mechanisms-for-antibiotic-reimbursement-in-the-united-states-cmss-ipps-fy2020-final-rule/ [Accessed 1 October 2022].
Rex J., 2020. Sweden To Test An Access-Focused Model For New Antibiotics: Contracting For Availability. [Online] Available at: https://amr.solutions/2020/03/16/sweden-to-test-an-access-focused-model-for-new-antibiotics-contracting-for-availability/
Reynolds C., Finkelstein J., Ray G. M. & S.S. H., 2014. Attributable healthcare utilization and cost of pneumonia due to drug-resistant streptococcus pneumonia: a cost analysis. Antimicrobial resistance and infection control, Volume 3, p. 16.24851182
Schneider M., 2020. New Rules Expand Application of the NTAP Program for Innovative Antibiotics. [Online] Available at: https://www.contagionlive.com/view/new-rules-expand-application-of-the-ntap-program-for-innovative-antibiotics
Shaarma A. , 2021. Menace of antimicrobial resistance in LMICs: Current surveillance practices and control measures to tackle hostility. Journal of Infection and Public Health, pp. 172–181.34972026
Shaw G., 2021. Act Now to Get Paid for Novel ABx Under NTAP. Pharmacy Practice News, 9 August .
Shlaes D. M., 2020. The Economic Conundrum for Antibacterial Drugs. Antimicrobial Agents and Therapy, pp. 1–7.
Shlaes D. M. & Bradford P. A., 2018. Antibiotics—From There to Where?: How the antibiotic miracle is threatened by resistance and a broken market and what we can do about it. Pathogens and Immunity, pp. 19–43.30993248
Shorr A., Zilberberg M., Micek S. & M.H K., 2015. Outcomes associated with bacteremia in the setting of methicillin-resistant Staphylococcus aureus pneumonia: a retrospective cohort study. Critical Care, Volume 19, p. 312.26335247
Simkins J., Muggia V., Cohen H. & Minamoto G., 2014. Carbapenem-resistant Klebsiella pneumoniae infections in kidney transplant recipients: a case-control study. Transplant Infectious Disease, Volume 16, pp. 775–82.25092500
Simoens S. & Spriet I., 2021. Guidance for Demonstrating the Societal Value of New Antibiotics. Frontiers in Pharmacology, Volume 11, p. 10.3389/fphar.2020.618238.
Singer T., 2022. Researcher Develops Technology to Advance Antibiotic Discovery. [Online] Available at: https://news.northeastern.edu/2017/03/21/researcher-develops-technology-to-advance-antibiotic-discovery/
Spellberg B., 2014. The Future of Antibiotics. Critical Care, 18(228), p. 10.1186/cc13948.
Tavadze M. , 2014. Risk factors for vancomycin-resistant enterococcus bacteremia and its influence on survival after allogeneic hematopoietic cell transplantation. Bone marrow transplantation, Volume 49, p. 1310–6.25111516
Alliance TB, 2020. TB Alliance Announces Partnership with Hongqi Pharma to Commercialize New Therapy for Highly Drug-Resistant Forms of TB in China. [Online] Available at: https://www.tballiance.org/news/tb-alliance-announces-partnership-hongqi-pharma-commercialize-new-therapy-highly-drug-resistant
Alliance TB, 2022a. Collaborating with PDPs. [Online] Available at: https://www.tballiance.org/rd/innovations/collaborating-pdps
Alliance TB, 2022b. Building the Largest TB Drug Portfolio. [Online] Available at: https://www.tballiance.org/content/building-largest-tb-drug-portfolio
Alliance TB, 2022c. Pretomanid and the BPaL Regimen. [Online] Available at: https://www.tballiance.org/access/pretomanid-and-bpal-regimen
Tedja R. , 2014. The impact of multidrug resistance on outcomes in ventilator-associated pneumonia. American Journal of Infection Control, Volume 42, pp. 542–545.24630700
Teillant A. G. S., Barter D., Morgan D. & Laxminarayan R., 2015. Potential burden of antibiotic resistance on surgery and cancer chemotherapy antibiotic prophylaxis in the USA: A literature review and modelling study.. The Lancet Infectious Diseases, Volume 15, p. 1429–37.26482597
Theuretzbacher U., 2017. Global antimicrobial resistance in Gram-negative pathogens and clinical need. Current Opinion in Microbiology, pp. 106–112.
Thomas D. & Wessel C., 2022. The State of Innovation in Antibacterial Therapeutics, s.l.: BIO Industry Analysis.
Thorpe K. E., Joski P. & Johnston K. J., 2018. Antibiotic-Resistant Infection Treatment Costs Have Doubled Since 2002, Now Exceeding $2 Billion Annually. Pharmaceuticals & Medical Technology, 37(4), pp. 662–669.
Totsika M., 2016. Benefits and Challenges of Antivirulence Antimicrobials at the Dawn of the Post-Antibiotic Era. Current Medicinal Chemistry, February, pp. 30–37.
Trevas D. , 2021. Diagnostic Tests Can Stem the Threat of Antimicrobial Resistance: Infectious Disease Professionals Can Help. Clinical Infectious Diseases, p. e893–e900.33206946
Trevas D. , 2021. Diagnostic Tests Can Stem the Threat of Antimicrobial Resistance: Infectious Disease Professionals Can Help. Clinical Infectious Diseases, 72(11), pp. e893 – e900.33206946
U.S. Food and Drug Administration, 2013. Non-Penicillin Beta-Lactam Drugs: A CGMP Framework for Preventing Cross-contamination, Silver Spring, MD: U.S. Food and Drug Administration, Center for Drug Evaluation and Research.
USP, 2022. U.S. Pharmacopeia Medicine Supply Map Analysis Shows Increased Shortage Risk for Antibiotics. [Online] Available at: https://www.usp.org/news/usp-medicine-supply-map-analysis-shows-increased-shortage-risk-for-antibiotics#:~:text=Rockville%2C%20MD%2C%20May%2024%2C,Medicine%20Supply%20Vulnerability%20Insights%20Series. [Accessed 2022 October 1 2022].
Vanderbeek A., Bliss J., Yin Z. & Yap C., 2022. Implementation of platform trials in the COVID-19 pandemic: A rapid review. Contemporary Clinical Trials, pp. 1–12.
Verma S., 2019. Aligning Payment And Prevention To Drive Antibiotic Innovation For Medicare Beneficiaries. Health Affairs, 2 August.
Wang E. , 2015. The ever-evolving landscape of candidaemia in patients with acute leukaemia: Non-susceptibility to caspofungin and multidrug resistance are associated with increased mortality. Journal of Antimicrobial Chemotherapy, Volume 70, pp. 2362–2368.25855759
Wang Z. , 2022. Bioinformatic prospecting and synthesis of a bifunctional lipopeptide antibiotic that evades resistance. Science, pp. 991–996.
Wenzler E., Goff D., Bazan J. & Bauer K., 2014. Clinical Outcomes in Patients With Ceftriaxone-Resistant Streptococcus pneumoniae Pneumonia. Infectious Diseases in Clinical Practice, Volume 22, pp. 263–266.
WHO, 2021. 2020 antibacterial agents in clinical and preclinical development: an overview and analysis. [Online] Available at: https://www.who.int/publications/i/item/9789240021303
World Health Organization, 2022. Target Product Profiles. [Online] Available at: https://www.who.int/observatories/global-observatory-on-health-research-and-development/analyses-and-syntheses/target-product-profile/who-target-product-profiles [Accessed 1 December 2022].
World Intellectual Property Organization, 2011. Medicines Patent Pool. [Online] Available at: https://www.wipo.int/edocs/mdocs/mdocs/en/wipo_gc_lic_ge_12/wipo_gc_lic_ge_12_ref_factsheet.pdf [Accessed 23 December 2022].
Wozniak T., Barnsbee L., Lee X. & Pacella R., 2019. Using the Best Available Data to Estimate the Cost of Antimicrobial Resistance: A Systematic Review. Antimicrobial Resistance & Infection Control, 8(26), pp. 10.1186/s13756-019-0472-z.
Yahav D., Tau N. & Shepshelovich D., 2020. Assessment of Data Supporting the Efficacy of New Antibiotics for Treating Infections Caused by Multidrug-resistant Bacteria. Clinical Infectious Diseases, pp. 1968–1974.
Zhu M. , 2021. The future of antibiotics begins with discovering new combinations. Annals of the New York Academy of Sciences, pp. 82–96.