# ACKNOWLEDGMENTS

We gratefully acknowledge Casey Sullivan (ASPE) and Amber Jessup (formerly at ASPE) for their leadership, guidance, and input to this study. We would like to thank members of the Project Advisory Group at the U.S. Department of Health and Human Services (HHS): John Farley, Thushi Amini, James Byrne, Michael L. Lanthier, Michael R. Craig, Sameer S. Kadri-Rodriguez, John A. Jernigan, Jeffrey Strich, Christopher Houchens, Mark Albrecht, Sue Cammarata, Alan (Laurence) Carr, Jessica Swenson, Ramya Gopinath, Elizabeth O'Shaughnessy, Dmitri Iarikov, Gilbert "Lynn" Marks (formerly at HHS), Tyler Merkeley (formerly at HHS), Stephen Murphy, Trinidad Beleche, Allison Kolbe, Erin Rubens (formerly at HHS), Aaron Kearsley, Sharon Arnold, and Jessica Marus. We also thank Mark Trusheim at Co-Bio Consulting and NEWDIGS at the MIT Center for Biomedical Innovation for his input on methodological considerations and feedback throughout the study.

The findings presented in this report were reviewed by Amitabh Chandra, Ph.D. (Harvard University), Rena Conti, Ph.D. (Boston University), Neeraj Sood, Ph.D. (University of Southern California), and R. Brett McQueen, Ph.D. (University of Colorado). We gratefully acknowledge their review and feedback.