# EXECUTIVE SUMMARY

The market for antimicrobial (AM) drugs is unique in that it is associated with a positive externality (public health)^1^ as well as a negative externality (antimicrobial resistance, or AMR) (Mossialos, et al., 2010). AMR occurs when microbes change over time and no longer respond to available medicine. There are several strategies for combatting AMR, including infection control and prevention, stewardship, development of new drug targets and novel treatment approaches, improving diagnostics, developing vaccines, and development of novel AM drugs. Development of novel AM drugs is especially urgent because there are only a limited number of new AM drugs that can treat the multi-drug resistant organisms (MDROs) listed on the WHO priority list (Dall, 2021). Most new AM drugs, however, are not novel, but primarily derivatives of existing AM drugs (Blaskovich, et al., 2017). In addition, AM manufacturers face numerous challenges that have resulted in 15 out of the 18 largest global pharmaceutical companies exiting AM research and development over the last 30 years (Dutescu & Hillier, 2021).

In this report, we examine the scientific, economic, and regulatory challenges in the U.S. market that have impeded the development of novel AM drugs. Our focus is on understanding the market challenges for development of drugs that treat MDRO infections that occur in hospitals in the U.S. and are reimbursed primarily through the diagnosis-related group (DRG) system. We also investigate possible interventions to address the market challenges identified. The objective of this work is to identify new approaches to encourage development of novel AM drugs that could be explored further.

## ES.1 METHODOLOGY

To improve understanding of the magnitude of the problem of AMR, we began our study with a scoping review of the literature published in the last 10 years to identify studies that quantify the externality posed by AMR in the U.S. drug market. We also reviewed recent literature on the scientific, economic, and regulatory challenges encountered in the AM drug market in the U.S. We supplemented this literature review with findings from an earlier study in 2018 for which we had conducted a series of semi-structured interviews with AM experts, including early stage developers, venture capitalists, doctors, and hospital representatives, to examine: (1) how drug companies and investors decide to invest in developing new AM drugs; (2) how health care providers determine the value of AM drugs and decide to prescribe them; and (3) what the barriers are to increased investment in AM drugs.

We also examined whether there has been a slowdown in the intensity of early stage AM drug discovery by looking at the number of AM drug compound patents filed and/or granted annually over the last 30 years using Espacenet’s searchable patent database. While patents are only one measure of interest in AM drug development and innovation, if AM drug patents are trending downward when patents for all other drugs are trending up, this could point to an allocation of development interest and resources away from AM drugs. To examine this potential market challenge, we compared trends in early stage AM drug discovery to trends in the non-AM biopharmaceutical market as a whole (i.e., all drugs, except for AM drugs grouped together) to evaluate: (1) if there is a slowdown in early-stage AM drug research and (2) if any slowdown is specific to AM drug research or more systemic across the industry.

Additionally, we conducted another series of semi-structured interviews with experts from different organizations to explore inefficiencies in the AM drug market that were not addressed during our previous research, as well as possible strategies for alleviating these inefficiencies (see Appendix A for our interview questions). Interviewees’ organizations included universities, biopharmaceutical companies, foundations, payers/health technology assessment (HTA) groups, and others.

## ES.2 SUMMARY OF SCOPING LITERATURE REVIEW FINDINGS

Our scoping review of studies that quantify the AMR externality in the U.S. indicate that the cost of AMR can be very high, although estimates vary widely (Naylor, et al., 2018; Johnson, et al., 2019; Thorpe, et al., 2018). The wide range in estimates is due to definitional differences in the studies, which make it difficult to quantify the problem accurately. Nonetheless, the potential magnitude of the problem is significant. It is therefore important to explore the challenges that impede AM drug development as well as possible interventions to address these challenges. These interventions could, in turn, reduce the AMR externality. While the difficulties encountered in the AM drug market are often characterized in the literature as a market failure, we argue that these difficulties are better characterized as market challenges because drug markets are not perfectly competitive markets and are all inherently subject to market failure.

According to Spellberg (2014), the challenges faced by the AM drug markets can be grouped into three major categories – scientific, economic, and regulatory. Some of the challenges can be classified in multiple categories (e.g., research and development challenges can be viewed as both scientific as well as economic challenges). Our literature review and 2018 study indicated that the major scientific challenges facing the AM drug development market in the U.S. include the difficult science of AM drug discovery, the lack of available diagnostic testing, and the length and expense of research and development. Economic challenges include, in addition to the costs of research and development, the lower return from AM drugs compared to other drugs due to the interrelated factors of low sales volume, lower rates of drug resistant infections in the U.S. (causing lower demand), and the current valuation of AM drugs by society. These economic challenges have resulted in numerous large companies shutting down their AM research in recent years, including Bristol-Myers Squibb, Novartis, AstraZeneca, Sanofi, and Allergan (Megget, 2018). The abandonment of AM drug development by these large companies may drive away further investment. Over 95 percent of the drugs in development today are being developed by small companies, and 70 percent of these companies are pre-revenue, which means they have no products on the market yet that they have developed and commercialized (Pew Trusts, 2021). Regulatory challenges include clinical trial requirements and reimbursement challenges associated with Medicare policies.

## ES.3 TRENDS IN AM DRUG DISCOVERY

While the AM drug market in the U.S. faces numerous challenges, AM drug compound patent data show that 2017 has been an inflection point in early drug discovery across the board with significant increases in the number of patents published per year for 2017 and onward. Further, the AM drug compound discovery trend broadly mirrors that of non-AM drug target compounds. Since 2010, there has been around a two-fold increase in the total number of AM and non-AM drug compound patents published worldwide, suggesting that the rates of discovery for new AM and non-AM drug compounds are similar overall. While patent data are only one measure of early-stage innovation activity in pharmaceutical markets, the data seem to point to continued interest in developing AM drugs. We acknowledge that the quality of these patents may also be changing over time. Despite the observed upward trend in the number of patents published, the trend for patent quality—if defined as patents for novel AM drug compounds—might be the reverse.^2^ Further research is needed to assess the quality of the patents and to determine who is filing these patents to better interpret these observed trends.

## ES.4 EXPERT INTERVIEWS

Our expert interviews provided additional perspectives about current challenges and possible interventions to address these challenges in AM drug markets. We asked questions about challenges specific to the U.S. market, as well as questions about eight additional topics to explore AM drug market challenges not addressed during our previous research, as well as other potential interventions that might encourage novel AM drug development. Some of the recommendations made are more developed (with initial efforts already underway) and “actionable” than others. A summary of these discussions is provided below.

Challenges Specific to the U.S. AM Market and Potential Government Interventions. Experts noted that one of the greatest challenges for the AM drug market is the structure of the current U.S. pharmaceutical business model, which results in insufficient returns to manufacturers of AM drugs. Suggested interventions included removing AM drugs from the Diagnosis-related Group (DRG) based reimbursement system, decoupling AM drug sales from volume sold, subsidizing post-market activities, and forming a public entity or public-private partnership for AM drug development.

Another challenge discussed by experts is that the clinical trial evidence of recently approved AM drugs does not show whether the new drug performs better than existing AM drugs to treat MDRO infections. Further, good stewardship requires older drugs to be used first (National Academies of Sciences, Engineering and Medicine, 2022). Experts who raised this point noted the importance of testing for superiority of new AM drugs, rather than non-inferiority; focusing on patient outcomes rather than the elimination of the pathogen, developing new platforms for discovering AM drugs, using clinical trial platforms and networks to generate higher quality evidence, and education of physicians about the benefit of new AM drugs over existing drugs.

Some experts also noted that the U.S. market size of drug resistant infections is too small to be of interest to manufacturers and is expected to shrink further with increased stewardship. One expert suggested changing the current for-profit business model to a non -profit one for any AM drugs that are unlikely to earn a profit due to small market size and publicly funding the development of those drugs. The 2022 National Academies report on combating AMR also suggested it might be possible that drugs with a very small market might be natural non-profits (i.e., it is not possible to profit from their sale) and an alternative might be to invest in a non-profit drug development organization (National Academies of Sciences, Engineering, and Medicine, 2022). Another expert suggested that government could help by assisting companies in accessing foreign markets, which see a greater number of cases. This expert noted that the small companies that have developed AM drugs do not have the presence in foreign markets or knowledge of regulatory affairs to access the insurance systems in those countries.

Experts also noted that AMR will need continued attention. While development of novel AM drugs is essential to treat MDRO infections, strategies must also be employed to combat continued growth of AMR and further growth in MDROs. Expert suggestions to combat AMR included effective oversight of stewardship programs, programs for improvements in hygiene and cleaning, funding research to reduce AMR, working with insurance companies to reduce overprescribing, strengthening surveillance systems, and appropriate use of diagnostics. One expert also noted the importance of relying less on AM drugs and more on developing anti-virulent drugs that interrupt the process of infection in the host.

Other Topics Related to AM Drug Development. Experts were also asked about other topics with respect to AM drug development, including innovation, the role of large companies, potential pull incentives (e.g., market entry reward (MER) models), open-source approaches to AM drug development, lessons learned from COVID-19, the role of public-private partnerships, stockpiling,, and manufacturing capacity for AM drugs.

Experts noted that governments can encourage innovation in AM drugs by funding clinical trial platforms, clinical trial networks (CTNs), and other forms of partnerships. Development of target product profiles (TPPs) for pharmaceutical developers can also be helpful in encouraging innovation.^3^

Most experts agreed that most large companies have lost interest in the AM drug market because the returns from AM drugs are small compared to other drugs. However, several experts thought that these companies may also see reputational value and recognize the threat of AMR and therefore will continue to be involved in other ways. One such way is the AMR Action Fund, a public-private partnership (PPP)^4^ investing in the development of AM therapeutics targeting life-threatening resistant infections.^5^

Push and pull incentives are described and reviewed in detail in the National Academies report on combating AMR and are not described in great detail in this report (National Academies of Sciences, Engineering and Medicine, 2022);instead we asked experts’ opinions about a few types of pull incentives, including market entry reward (MER) models.^6^. Some experts were supportive of MER models whereas others noted significant challenges that still need to be addressed, including the complexity of full de-linkage of AM drug sales and volume, lack of accessibility for small companies, lack of clarity in MER procurement, difficulty in establishing eligibility criteria and reward amounts, inability to sustain AM drug development, need for quality clinical evidence, insufficient support for post-approval requirement expenses, cost, and lack of improved patient access. During these discussions, one expert also mentioned that the New Technology Add-on Payments (NTAP) mechanism, which provides additional reimbursement for some novel AM drugs, has recently worked for some hospitals, and should be explored further. Interestingly, experts we interviewed in 2018 said this mechanism had been generally unsuccessful. However, experts we interviewed in 2022 noted that NTAP had recently become easier to access, which might explain this difference in opinion.

When asked about the possibility of an open source approach to AM drug development, experts unanimously agreed that the open source approach to AM drug development ― in which all data and ideas are shared without intellectual property (IP) protection― would not be realistic given the importance of IP protection to the AM drug market and to pharmaceutical innovation.

Experts were also asked whether the COVID-19 pandemic provided any useful lessons for stimulating AM drug development to combat AMR. Although the market for AM drugs is much smaller and vaccine development is vastly different from AM drug development, experts noted that the pandemic response to COVID-19 showed the potential success of public-private partnerships (PPPs), such as those between the U.S. government and Moderna. Other lessons learned from COVID-19 included the value of the high level of clinical evidence generated for the vaccines and the transparency of government in its actions, as these factors were very helpful in encouraging use of the new vaccines. A similar focus during novel AM drug development could encourage use of new AM drugs as well. Clinical trial platforms^7^ and clinical trial networks (CTNs)^8^ surged during COVID-19 and could have potential benefit for AM drug development. Other experts also mentioned the benefits of CTNs based on the success observed during the pandemic.

We asked several questions about the role of PPPs in AM drug development. Several experts recognized the value of PPPs, such as Combating Antibiotic Resistant Bacteria Biopharmaceutical Accelerator (CARB-X) and Global Antibiotic Research & Development Partnership (GARDP), in encouraging novel AM drug development. As noted previously, experts discussed the success of PPPs formed during the COVID-19 pandemic and a few also reported on the successes of the TB Alliance.

When asked about whether the government should focus on stockpiling AM drugs experts agreed that stockpiles may not be the best way to address future surge needs or to serve as a pull incentive because of the difficulty of predicting how AMR will evolve over time and the inherent challenge in anticipating which drug and how much of that drug is needed.

When asked about manufacturing capacity for AM drugs for emergency preparedness purposes, all experts felt strongly about the importance of preparing for a surge need for AM drugs. Manufacturing capacity is currently largely located offshore, and government could support development of a U.S. supply chain for the manufacturing of AM drugs, using creative approaches that might, for example, repurpose facilities for other uses when not needed for AM drug manufacturing.

Table E - 1 summarizes the market challenges and possible interventions that experts discussed during our interviews. As noted in the table, some groundwork has already been done on several interventions. These could be further examined to assess the potential benefit of the interventions. Many of the interventions listed are conceptual and need to be developed in greater detail (e.g., forming a new government entity and strengthening surveillance systems). Several proposed interventions are also synergistic and therefore need sequential implementation, whereas others could be implemented simultaneously. For example, diagnostics will be needed for pathogen detection to effectively run CTNs and establish superiority evidence needed by physicians to encourage use of a new AM drug. This may also require the development of new diagnostics if existing diagnostics cannot be used.

Table E - 1 Possible Interventions to Address AM Market Challenges as Suggested by Experts Interviewed in 2022

Market Challenge | Intervention | Existing Data to Support Intervention
Market structure, conduct, and performance of the U.S. AM drug industry | Remove AM drugs from the DRG reimbursement system | Some success with the NTAP system
Market structure, conduct, and performance of the U.S. AM drug industry | Change to a market model delinked from sales | UK/Sweden testing these market models
Market structure, conduct, and performance of the U.S. AM drug industry | Subsidies (e.g., in form of priority vouchers) | Already in use to encourage development of drugs for neglected diseases
Market structure, conduct, and performance of the U.S. AM drug industry | Formation of new public entity to manage AM drug portfolio
Insufficient clinical evidence on added clinical benefit at time of regulatory approval | Use of diagnostics and clinical trial networks | HIV Clinical Trial Networks, National Cancer Institute National Clinical Trials Network
Insufficient clinical evidence on added clinical benefit at time of regulatory approval | Test for superiority rather than non-inferiority
Insufficient clinical evidence on added clinical benefit at time of regulatory approval | Focus on patient outcomes rather than pathogens
Insufficient clinical evidence on added clinical benefit at time of regulatory approval | Develop new platforms for discovering new drugs
Insufficient clinical evidence on added clinical benefit at time of regulatory approval | Provide information to physicians about AM drugs
Small market size – relatively low number of drug-resistant infections in the U.S. | Categorize some AM drugs as not profitable and use a not-for-profit business model for development
Small market size – relatively low number of drug-resistant infections in the U.S. | Assist small drug companies with access to larger foreign markets.
Threat of an increase in antimicrobial resistance (AMR) | Development of diagnostics | Employed by other countries to manage AMR (e.g., Norway and Sweden)
Threat of an increase in antimicrobial resistance (AMR) | Greater oversight of stewardship programs
Threat of an increase in antimicrobial resistance (AMR) | Strengthening surveillance systems
Threat of an increase in antimicrobial resistance (AMR) | Increased investments in policies that combat AMR (e.g., limiting use of AM drugs in agriculture, improvements in hygiene)
Threat of an increase in antimicrobial resistance (AMR) | Development of anti-virulent drugs

1 All infectious disease drugs, not just AM drugs, have positive externalities because their use reduces the chance of transmitting the disease to others.

2 Several studies have shown that there is large degree of inherent variability in published patent quality and different perspectives on what actually constitutes “quality” (Guerrini, 2014; Khanna, 2019).

3 According to the World Health Organization (WHO) a target product profile (TPP) “outlines the desired ‘profile’ or characteristics of a target product that is aimed at a particular disease or diseases. TPPs state intended use, target populations and other desired attributes of products, including safety and efficacy-related characteristics” and can help guide research and development activities (World Health Organization, 2022).

4 A public-private partnership (PPP) is a collaboration between a government agency and a private entity to provide a public asset or service. In a PPP, the private party takes on significant risk and management responsibility for the project. It is typically a long-term contract.

5 The mission of the AMR Action Fund is to develop and introduce two to four new AM agents within the next ten years, and to create a sustainable system for investing in and promoting innovation in this field to address the threat of growing resistance (AMR Action Fund, 2022).

6 These involve financial rewards made to the developer or intellectual property (IP) holder for obtaining regulatory approval for marketing an AM drug that meets pre-defined criteria, such as novelty, ability to treat a life-threatening resistant infection, etc.

7 A clinical trial platform is a system or infrastructure that supports the conduct of clinical trials. This can include technology for managing and analyzing data, coordinating research activities, and ensuring compliance with regulatory standards. A clinical trial platform may be used to facilitate collaboration among multiple research organizations, and to streamline the process of conducting clinical trials. The goal of a clinical trial platform is to improve the efficiency and effectiveness of clinical research.

8 A clinical trial network is a group of research organizations that collaborate to conduct clinical trials. This can include hospitals, clinics, academic institutions, and other organizations involved in medical research. The goal of a clinical trial network is to pool resources and expertise to conduct clinical trials more efficiently and effectively. By working together, clinical trial networks can increase the scope and reach of clinical research and improve the speed at which new treatments are developed and tested.