# 3 METHODOLOGY

We first conducted a scoping review of the literature published in the last 10 years to identify studies that provide empirical evidence of the negative externality posed by AMR in the U.S. AM drug market. We searched PubMed, Google Scholar, and the grey literature via Google, using a variety of search term combinations, such as market failure, market challenges, market inefficiencies, antibiotic, antimicrobial, quantification, and interventions. In addition, we reviewed the cited references to identify additional literature of interest.

We also examined whether there has been a slowdown in the intensity of early stage AM drug discovery by looking at the number of AM drug compound patents filed and/or granted annually over the last 30 years using Espacenet’s searchable patent database. We then compared the early stage AM drug discovery trends to that of the non-AM biopharmaceutical market (i.e., all drugs, except for AM drugs grouped together) to evaluate: (1) whether there is a slowdown in early-stage AM drug discovery and (2) whether any slowdown is specific to AM drug discovery or more systemic across the industry.

We also conducted a review of the recent literature on the scientific, economic, and regulatory challenges encountered in the AM drug development market in the U.S. We supplemented this literature review with findings from a 2018 study for which we conducted a series of semi-structured interviews with AM experts, including early stage developers, venture capitalists, doctors, and hospital representatives, to examine: (1) how drug companies and investors decide to invest in developing new AM drugs; (2) how health care providers determine the value of and decide to prescribe AM drugs; and (3) what barriers exist to increased investment in AM drugs.

Next, we conducted another series of semi-structured interviews with experts from different organizations to explore the inefficiencies in the AM drug market not addressed during our previous research, as well as potential strategies for alleviating these inefficiencies (see Appendix A for our interview questions). These groups included academics, biopharmaceutical companies, foundations, payers/health technology assessment (HTA) groups, and others (Table 1).

Table 1 Anonymized List of Experts Interviewed in 2022, by Group

Group | Job Title | Expert
Group 1 – Academia | Professor | Academic 1 (A1)
Group 1 – Academia | Professor | Academic 2 (A2)
Group 1 – Academia | Professor | Academic 3 (A3)
Group 1 – Academia | Professor | Academic 4 (A4)
Group 1 – Academia | Postdoctoral fellow | Academic 5 (A5)
Group 2 – Biopharmaceutical Company | CEO | Biopharmaceutical Company 1 (BC1)
Group 2 – Biopharmaceutical Company | CEO | Biopharmaceutical Company 2 (BC2)
Group 2 – Biopharmaceutical Company | CEO | Biopharmaceutical Company 3 (BC2)
Group – 3 Foundation | Director | Foundation 1 (F1)
Group 4 – Payer/HTA | Program Director | Payer/HTA 1^*^ (P1)
Group 4 – Payer/HTA | Consultant Clinical Advisor | Payer/HTA 2^*^ (P2)
Group 5 – Other | Senior Advisor at a Public Health Agency | Other 1 (O1)
Group 5 – Other | Subject Matter Expert/CEO | Other 2 (O2)
Group 5 – Other | Senior Clinical Subject Matter Expert | Other 3 (O3)
Group 5 – Other | Director of a Public Health Organization | Other 4 (O4)
Group 5 – Other | Clinical Trials Network Principal Investigator | Other 5 (O5)

* Two individuals at the same organization