# 2 STUDY OBJECTIVES

Novel AM drugs are needed to deal with AMR, yet many of the recently approved AM drugs are primarily derivatives of existing AM drugs. Furthermore, there are only a few new AM drugs against the MDROs listed on the WHO priority list (Dall, 2021). These MDRO infections are typically treated at hospitals, which creates additional challenges associated with reimbursement, as described in detail below. This report focuses on the scientific, economic, and regulatory challenges that impede the development of novel AM drugs needed to treat MDRO infections, as well as potential interventions that could address these issues.

The report begins with a discussion of quantifying the AM market externalities; trends in early AM drug discovery are then explored through an analysis of patents. The report then summarizes prior research on scientific, economic, and regulatory challenges in the AM drug market. Finally, the report describes the results of expert interviews on several new topics related to market challenges for AM drug development, including experts’ opinions on potential options to address those challenges.