# 1 INTRODUCTION

The consensus view among many stakeholders is that not enough antimicrobial (AM) drugs are being developed to address current and future drug-resistant infections. There are scientific, economic, and regulatory challenges in the U.S. market that have impeded the development of novel AM drugs. It is important to understand these challenges and to identify new ways to encourage development of novel AM drugs because there are few available treatments for multi-drug resistant organism (MDRO) infections that occur in U.S. hospitals.

## 1.1 NOVEL AM DRUG DEVELOPMENT IS NOT KEEPING PACE WITH NEED

A unique and major challenge to the AM drug market is that of AMR. Any use of AM drugs can lead bacteria or fungi to evolve resistance to those drugs (Moran, 2019). The decision to use AM drugs however does not incorporate the social cost of the depletion of AM drug effectiveness. AMR can be addressed in a variety of ways, including social, cultural, and economic factors (Minssen, et al., 2020). For example, disease prevention and response, infection control, and stewardship are all effective ways to reduce AMR.

Development of novel AM treatments, however, is essential to treat patients with MDRO infections. The preclinical pipeline and to some extent the clinical pipeline look promising according to experts we interviewed and a recent WHO report (WHO, 2021), but it is a common concern that the current pipeline may not yield enough novel AM drugs to address the bacterial pathogens that are developing resistance or may do so in the future (Hutchings, et al., 2019; Shlaes & Bradford, 2018). Furthermore, while additional treatments for most drug resistant infections exist if first-line treatments fail, many of these have serious side effects (CDC, 2021).

In 2018, we interviewed a variety of stakeholders to examine how drug companies and investors decide to invest in developing new AM drugs, how health care providers determine the value of and decide to prescribe AM drugs, and what barriers exist to increased investment in AM drugs (Eastern Research Group, Inc., 2018). Most of the doctors interviewed described a need at their institution for new AM drugs. Many said that their prescribing options are often restricted due to patients being allergic (or saying they are allergic) to many AM drugs. Having more AM options—particularly more oral AM drug options—to prescribe to patients with allergies would be immensely helpful. Often the only viable AM drugs for patients with allergies are IV-only formulations that cause the patient to stay in the hospital. Based on our interviews of doctors in 2018, another reason doctors need more AM drug options is the perceived increase in prevalence of MDROs in urban settings. Not having enough viable options to treat resistant infections can lead doctors to prescribe medications that have substantial side effects. For example, some doctors have resorted to using older AM drugs like polymyxin to treat resistant infections, even though polymyxin can cause kidney failure. Thousands of patients are treated with these older AM drugs each year and, in addition to the quality of life impacts for the patients, hospitals have to bear the significant costs of dealing with the side effects, such as putting children on dialysis.

## 1.2 MARKET FAILURE IS THE NORM FOR ALL BIOPHARMACEUTICAL MARKETS

The difficulties encountered in the AM drug market are often characterized in the literature as a market failure. Given that no drug markets are perfectly competitive and are all subject to market failure, we focus here on articulating the market challenges that are specific to AM drugs.

According to economic theory, a perfectly competitive market, comprising producers and consumers each acting in their own self-interest, yields an optimal allocation of goods and services. However, for a market to be considered perfectly competitive, four conditions must be present: (1) there needs to be a large number of producers and consumers of the good or service in question, with no producer or consumer having any influence on the market; (2) both producers and consumers should be able to enter or exit the market without any restrictions; (3) an enforceable property rights system needs to be in place, such that the good or service is not free (i.e., consumers need to pay to use the good or service); and (4) there should be no informational asymmetries, i.e., both consumers and producers have access to all relevant information, such as prices and costs, to make rational decisions about the good or service being bought and sold (Rattinger, et al., 2008). A market failure results when at least one of these conditions is violated, leading to a net social welfare loss (the market provides a sub-optimal quantity of the good or service). Situations that violate one or more of these conditions include (Bækkeskov, 2019):

▪ Increasing economies of scale in production. When economies of scale increase regardless of production, market forces lead to monopoly production, resulting in suboptimal levels of production and consumption.
▪ Public goods. Private markets underinvest in goods that are non-excludable (no person can be excluded from using it), non-rival (one person using the good does not prevent another from using it), and non-rejectable (no person can reject using the good) even though these goods are socially beneficial.
▪ Production or consumption externalities. Production and/or consumption of certain goods can create unintended consequences for third parties not involved in the market transaction. Because the free-market costs and prices, which are based on the laws of supply and demand, do not account for these impacts, markets allocate resources toward negative externalities and away from positive externalities, relative to the social optimum.
▪ Risk and uncertainty. When there is risk or uncertainty associated with the production or consumption of a good or service, a market may fail to emerge due to transaction costs or asymmetry of information.

Perfectly competitive markets serve as a benchmark for economic performance, but rarely exist in real life. Thus, market failure, as defined above, is not an exception but the norm for most markets, and the biopharmaceutical market is no exception due to several factors. First, the number of producers in the biopharmaceutical market for a given drug is limited (for brand drugs, there is only one producer) and there is no perfect substitute for the drug. Further, entry barriers, such as large capital investments needed for research and development, patents, and FDA-granted exclusivities, can preclude other producers from entering a market for several years. Combined, these structural characteristics of the biopharmaceutical market enable innovator firms (i.e., producers of brand drugs) to realize “…higher profits than would be possible in a purely competitive marketplace with many producers” (Rattinger, et al., 2008). It is often argued that such high profits are needed to incentivize producers to invest in research and development for new biopharmaceuticals to improve public health. Second, there is informational asymmetry among the producer, prescribers (clinicians), and consumers (patients) of a given drug. Incomplete and/or inaccurate information about a given drug could lead to suboptimal market outcomes. Third, federal and state governments influence buying and selling of a given drug through supply side regulations, such as research and development tax credits, orphan drug development tax credit, etc., and demand-side regulations, such as Medicare Part B, Part D, and Medicaid programs. Additionally, third-party insurers aim to get “…patients to use those drugs that are deemed necessary and cost effective to a greater extent” (Rattinger, et al., 2008) through various cost-sharing mechanisms, such as coinsurance, deductibles, tiered formularies, and prior authorization. These all influence the price and ultimately the supply as well as the demand for a given drug.

## 1.3 AM DRUG DEVELOPMENT HAS UNIQUE MARKET CHALLENGES

By virtue of being a biopharmaceutical market, the AM drug market is not a perfectly competitive market and subject to market failure. Market failure is therefore not a condition unique to the AM drug market. What is unique about the market for AM drugs is that it is associated with a positive externality (public health)^9^ as well as a negative externality (antimicrobial resistance or AMR) (Mossialos, et al., 2010). The positive externality arises because the use of a given AM drug by one patient reduces the chance of others catching that strain of bacteria from that patient. Additionally, the use of the given AM drug reduces the development of resistance to other AM drugs and could prevent cross-resistance within existing classes of AM drugs (Simoens & Spriet, 2021). On the negative side, when one patient uses an AM drug, a small number of bacteria become resistant to the treatment; the patient can then transmit resistant bacteria to others. Because such resistant bacteria will have a strong selective advantage over time, eventually other people will be unable to benefit from the use of the same AM drug, further perpetuating the problem and creating a negative externality. This negative externality could also be amplified through development of cross-resistance with the use of the AM drug in question, reducing the effectiveness of other AM drugs. One way to mitigate this negative externality is to introduce novel AM drugs that can treat resistant drug infections, which is discussed further below.

9 All infectious disease drugs, not just AM drugs, have positive externalities because their use reduces the chance of transmitting disease to others.