# APPENDIX A INTERVIEW GUIDE

The lack of available AM drugs to meet current and future threats of AM resistance is often attributed to a number of inefficiencies in the AM drugs market. According to Spellberg (2014), the causes of these inefficiencies can be divided into scientific, economic, and regulatory barriers and there may be others. The barriers include:

▪ Scientific barriers such as a lack of innovation that leads to drugs in the pipeline that are modifications of already existing drugs (which will not be able to address the problem of AM resistance in the long term),
▪ Economic barriers such as high research and development costs and low prices, DRG reimbursement, short treatment duration, and AM stewardship,
▪ Regulatory barriers such as burdensome clinical trial design.

These are common discussion points to explain the difficulties in bringing AM drugs to market.

ERG has been contracted by the US Department of Health and Human Services (HHS) Office of the Assistant Secretary for Planning and Evaluation (ASPE) to evaluate the inefficiencies in antimicrobial drug markets. The objective of our research is to identify AM drug market inefficiencies that may be candidates for government interventions to correct those inefficiencies. To this end, we have developed a list of questions to probe issues beyond those most commonly discussed where government intervention may play a role, as follows:

1. Beyond the issues most commonly discussed (lack of innovation, low returns, etc.), what are the challenges facing the U.S. AM drug market? What type of government interventions can be instituted to alleviate these challenges?
2. Large biopharmaceutical companies have withdrawn from direct investment in AM drug development but are still investing indirectly (e.g., AMR fund). What do you think their continued interest is driven by?
3. The preclinical pipeline for AM drugs is diverse, with many promising scientific concepts. Based on the 2020 WHO report on the global preclinical AM pipeline, currently there are 292 preclinical candidates across many new modalities (vaccines, antimicrobial peptides, bacteriophages, virulence inhibitors, immunomodulatory compounds) plus evolution of existing mechanisms. In addition, nanotechnology is being studied as a potential solution, including particles of liquid metal to shred bacteria and gold nanoclusters to inhibit bacteria.
  a. Do you think that innovation in the preclinical pipeline as just described can address the problem of AMR?
  b. Do you know of other promising innovations that could potentially address AMR?
  c. What can be done by government to encourage promising scientific discoveries in the preclinical pipeline to progress towards IND-ready candidates? Could changes in clinical trial requirements accelerate development and approval?
  d. How can early stage innovation in new technologies be encouraged?
4. Given the reported challenges in bringing AM drugs to market, should the government focus on developing a stockpile of novel AM drugs and/or AM drug technologies that can address AMR if there is a surge need due to an AMR public health emergency? If so, what features do you think are important in a program like that?
5. Do you think a Market Entry Reward (MER) program that delinks payment for AM drugs from level of use can address the economic challenge of bringing AM drugs to market (e.g., subscription model, prizes, etc.)?
  a. Do you have a preference for one of these models or another not named above?
  b. What are the risks associated with that model?
  c. How does one ensure that only truly novel AM drugs with added clinical benefit are awarded payments when robust clinical evidence for the drug’s ability to meet an unmet need and/or treat life-threatening bacterial infections is lacking at the time of regulatory approval?
6. Product development partnerships that formed in response to COVID were helpful to meet surge need for the vaccines and other treatments. Are these type of partnerships transferable to AM drug development?
  a. If so, what lessons could be transferred to the development of new and novel AM drugs?
  b. What other aspects of what we learned during COVID might be useful to stimulate AM drug development to combat AMR?
7. Some have proposed the formation of public benefit corporations (a hybrid of for- and non-profit corporation). Others support the use of a fully non-profit model (e.g., GARDP is one example of such model that aims to develop five new AM drugs by 2025). What are your thoughts on the relative success of these types of models?
8. Some advocate adopting an open approach to AM drug research and development in which all data and ideas are shared, and advances are not protected by patents (Klug, et al., 2021). In your opinion, is such an approach economically feasible and palatable to an industry where intellectual property (IP) outcomes are the main metrics of success?
9. We learned from COVID that the government was not well-prepared to provide surge capacity in terms of available manufacturing facilities, although they subsidized manufacturing expansion for commercial firms. Do you think that manufacturing capacity for AM drugs should be addressed now to support manufacturing during a public health emergency and if so, how (e.g., expand domestic manufacturing capacity, building domestic supply chains, invest in advanced manufacturing techniques, etc.)?