# LIST OF ACRONYMS

AM: Antimicrobial
AMC: Advance Market Commitment
AMR: Antimicrobial Resistance
ASPE: HHS Office of the Assistant Secretary for Planning and Evaluation
ASPR: HHS Administration for Strategic Preparedness and Response
BARDA: HHS Biomedical Advanced Research and Development Authority
BSI: Bloodstream infection
CARB-X: Combating Antibiotic Resistant Bacteria
CBER: FDA’s Center for Biologics Evaluation and Research
CDC: Centers for Disease Control and Prevention
CDER: FDA’s Center for Drug Evaluation and Research
CMS: Centers for Medicare and Medicaid Services
CPC: Cooperative Patent Classification
CRE: Carbapenem-resistant Enterobacterales
CRKP: Carbapenem-resistant K. pneumoniae
CRO: Clinical Research Organization
CTN: Clinical Trial Network
DRG: Diagnosis-related group
ECRAID: European Clinical Research Alliance on Infectious Diseases
ERG: Eastern Research Group, Inc.
ESBL: Extended-spectrum beta-lactamase
FDA: U.S. Food and Drug Administration
GARDP: Global Antibiotic Research and Development Partnership
GDP: Gross Domestic Product
HAI: Healthcare-acquired Infection
HHS: U.S. Department of Health and Human Services
HIV: Human Immunodeficiency Virus
HTA: Health technology assessment
ICU: Intensive Care Unit
IND: Investigational New Drug
IPPS: Inpatient Prospective Payment System
IQR: Inter-quartile Range
IV: Intravenous
MDRO: Multi-drug Resistant Organism
MER: Market Entry Reward
MIC: Minimum Inhibitory Concentration
MRSA: Methicillin-resistant Staphylococcus aureus
MSSA: Methicillin-susceptible Staphylococcus aureus
NASEM: National Academies of Sciences, Engineering, and Medicine
NDA: New Drug Application
NHS: National Health Service
NICE: U.K. National Institute for Health and Care Excellence
NIH: National Institutes of Health
NPO: Non-profit Organization
NTAP: New Technology Add-on Payments
PASTEUR: Pioneering Antimicrobial Subscriptions to End Upsurging Resistance
PDP: Product development partnership
PPP: Public private partnership
R&D: Research and development
QIDP: Qualified infectious disease product
SARS: Severe Acute Respiratory Syndrome
SLI: Second-line
SME: Small- and Medium-sized Enterprise
TB: Tuberculosis
TPP: Target Product Profile
VRE: Vancomycin-resistant enterococci
WHO: World Health Organization
XDR: Extensively Drug Resistant