# 7 REFERENCES

Ahn, J. ., 2014. Risk factors for the acquisition of carbapenem-resistant Escherichia coli at a tertiary care center in South Korea: a matched case-control study. American journal of infection control, 42(6), pp. 621–625.24837112
Akhabue, E. ., 2011. Cefepime-resistant Pseudomonas aeruginosa. Emerging infectious diseases, 17(6), pp. 1037–1043.21749765
Alawieh, A. ., 2015. A computational model to monitor and predict trends in bacterial resistance. Journal of global antimicrobial resistance, 3(3), pp. 174–183.26640775
Almomani, B. ., 2015. Incidence and predictors of 14-day mortality in multidrug-resistant Acinetobacter baumannii in ventilator-associated pneumonia. Journal of infection in developing countries, 9(12), pp. 1323–1330.26719938
Alvarez-Uria, G., Gandrab, S., Mandald, S. & Laxminarayan, R., 2018. Global forecast of antimicrobial resistance in invasive isolates of Escherichia coli and Klebsiella pneumoniae. International Journal of Infectious Diseases, Volume 68, p. 50–53.29410253
Amanati, A. ., 2021. Bloodstream infections in adult patients with malignancy, epidemiology, microbiology, and risk factors associated with mortality and multi-drug resistance. BMC infectious diseases, 21(1).
Anunnatsiri, S. & Tonsawan, P., 2011. Risk factors and clinical outcomes of multidrug-resistant Acinetobacter baumannii bacteremia at a university hospital in Thailand. The Southeast Asian journal of tropical medicine and public health, 42(3), pp. 693–703.21706949
Apisarnthanarak, A. ., 2007. Risk factors for and outcomes of healthcare-associated infection due to extended-spectrum beta-lactamase-producing Escherichia coli or Klebsiella pneumoniae in Thailand. Infection control and hospital epidemiology, 28(7), pp. 873–876.17564993
Ascension Wisconsin Library, 2022. Evidence-Based Practice: Levels of Evidence and Study Designs. [Online] Available at: https://ascension-wi.libguides.com/ebp/Levels_of_Evidence [Accessed 20 October 2022].
Aslam, B. ., 2018. Antibiotic resistance: a rundown of a global crisis. Infection and drug resistance, Volume 11, pp. 1645–1658.30349322
Aviv, T. ., 2018. The epidemiological impact and significance of carbapenem resistance in Pseudomonas aeruginosa bloodstream infections: a matched case-case-control analysis. Infection control and hospital epidemiology, 39(10), pp. 1262–1265.30103833
Aydemir, H. ., 2012. Mortality attributable to carbapenem-resistant nosocomial Acinetobacter baumannii infections in a Turkish university hospital. Japanese journal of infectious diseases, 65(1), pp. 66–71.22274161
Balkhair, A. ., 2019. Prevalence and 30-day all-cause mortality of carbapenem-and colistin-resistant bacteraemia caused by Acinetobacter baumannii, Pseudomonas aeruginosa, and Klebsiella pneumoniae: Description of a decade-long trend. International journal of infectious diseases, Volume 85, pp. 10–15.31100418
Baran, G. ., 2008. Risk factors for nosocomial imipenem-resistant Acinetobacter baumannii infections. International journal of infectious diseases, 12(1), pp. 16–21.17513154
Ben-David, D. ., 2012. Outcome of carbapenem resistant Klebsiella pneumoniae bloodstream infections. Bacteriology, 18(1), pp. 54–60.
Blanco, N. ., 2018. Risk Factors and Outcomes Associated with Multidrug-Resistant Acinetobacter baumannii upon Intensive Care Unit Admission. Antimicrobial agents and chemotherapy, 62(1).
Blanquart, F., Lehtinen, S. & Fraser, C., 2017. An evolutionary model to predict the frequency of antibiotic resistance under seasonal antibiotic use, and an application to Streptococcus pneumoniae. Proceedings of the Royal Society B: Biological Sciences, 284(1855), p. 20170679.
Borgatta, B. ., 2017. The clinical significance of pneumonia in patients with respiratory specimens harbouring multidrug-resistant Pseudomonas aeruginosa: a 5-year retrospective study following 5667 patients in four general ICUs. European journal of clinical microbiology & infectious diseases, 36(11), pp. 2155–2163.28624864
Brahmi, N. ., 2007. Epidemiology and risk factors for colonization and infection by Acinetobacter baumannii in an ICU in Tunisia, where this pathogen is endemic. Journal of infection and chemotherapy, 13(6), pp. 400–404.18095089
Branch-Elliman, W. ., 2013. Health and Economic Burden of Post-Partum Staphylococcus aureus Breast Abscess. PLoS ONE, 8(9), p. e73155.24039877
Brigmon, M. ., 2015. Impact of fluoroquinolone resistance in Gram-negative bloodstream infections on healthcare utilization. Clinical microbiology and infection, 21(9), pp. 843–849.26003282
Brizendine, K. D., Richter, S. S., Cober, E. D. & van Duin, D., 2015. Carbapenem-resistant Klebsiella pneumoniae urinary tract infection following solid organ transplantation. Antimicrob Agents Chemother, 59(1), pp. 553–557.25385105
Brotfain, E. ., 2017. Multidrug Resistance Acinetobacter Bacteremia Secondary to Ventilator-Associated Pneumonia: Risk Factors and Outcome. Journal of intensive care medicine, 32(9), pp. 528–534.26902255
Budak, S. ., 2014. The determination of carbapenem resistance in Escherichia coli and Pneumoniae isolates related to nosocomial infections and the evaluation of risk factors. The Southeast Asian journal of tropical medicine and public health, 45(1), pp. 113–122.
Burnham, J. P., Olsen, M. A. & Kollef, M. H., 2019. Re-estimating annual deaths due to multidrug-resistant organism infections. Infection Control & Hospital Epidemiology, Volume 40, pp. 112–113.30463634
Cai, B. ., 2017. Prevalence of Carbapenem-Resistant Gram-Negative Infections in the United States Predominated by Acinetobacter baumannii and Pseudomonas aeruginosa. Open Forum Infectious Diseases, 4(3), pp. 1–7.
Camins, B. ., 2011. The clinical impact of fluoroquinolone resistance in patients with E coli bacteremia. Journal of hospital medicine, 6(6), pp. 344–349.21834116
Cassini, A. ., 2019. Attributable deaths and disability-adjusted life-years caused by infections with antibiotic-resistant bacteria in the EU and the European Economic Area in 2015: a population-level modelling analysis. Lancet Infectious Disease, Volume 19, pp. 56–66.
CDC, 2017. Antibiotic Use in the United States, 2017, Atlanta, GA: US Department of Health and Human Services, CDC.
CDC, 2019. Antibiotic Resistance Threats in the United States, Atlanta: U.S. Department of Health and Human Services, CDC.
CDC, 2020. Lab Capacity: Antibiotic Resistance Laboratory Network (AR Lab Network). [Online] Available at: https://www.cdc.gov/drugresistance/solutions-initiative/ar-lab-network.html
CDC, 2021. About NHSN. [Online] Available at: https://www.cdc.gov/nhsn/about-nhsn/index.html [Accessed 9 July 2021].
CDC, 2021. FAQs for Clinicians about C. diff. [Online] Available at: https://www.cdc.gov/cdiff/clinicians/faq.html#treated
CDC, 2022a. EIP Network Activities. [Online] Available at: https://www.cdc.gov/ncezid/dpei/eip/eip-network-activities.html [Accessed 4 November 2022].
CDC, 2022c. About NARMS: Tracking Trends in Resistance. [Online] Available at: https://www.cdc.gov/narms/about/index.html [Accessed 4 November 2022].
CDC, n.d. Antibiotic Resistance & Patient Safety Portal. [Online] Available at: https://arpsp.cdc.gov/ [Accessed 9 July 2021].
CDC, n.d. Antibiotic Use. [Online] Available at: https://arpsp.cdc.gov/profile/antibiotic-use/all-classes?class-select-community=&dem-select-changes-topic=age220&tabsection-30=1
Centers for Disease Control and Prevention, 2022b. Tuberculosis - Data and Statistics. [Online] Available at: https://www.cdc.gov/tb/statistics/default.htm [Accessed 4 November 2022].
Chang, H. ., 2011. Mortality risk factors in patients with Acinetobacter baumannii ventilator: associated pneumonia. Journal of the Formosan Medical Association, 110(9), pp. 564–571.21930066
Chang, Y. ., 2015. Clinical features of patients with carbapenem nonsusceptible Klebsiella pneumoniae and Escherichia coli in intensive care units: a nationwide multicenter study in Taiwan. Journal of microbiology, immunology, and infection, 48(2), pp. 219–225.
Chaves, L. ., 2017. High mortality of bloodstream infection outbreak caused by carbapenem-resistant P. aeruginosa producing SPM-1 in a bone marrow transplant unit. Journal of Medical Microbiology, Volume 66, pp. 1722–1729.29095142
Chen, Z. ., 2019. The impact of carbapenem-resistant Pseudomonas aeruginosa on clinical and economic outcomes in a Chinese tertiary care hospital: A propensity score-matched analysis. American journal of infection control, 47(6), pp. 677–682.30554879
Chittawatanarat, K. ., 2014. Microbiology, resistance patterns, and risk factors of mortality in ventilator-associated bacterial pneumonia in a Northern Thai tertiary-care university based general surgical intensive care unit. INFECTION AND DRUG RESISTANCE, 7(0), pp. 203–210.25152627
Choi, S., Cho, E., Chung, J. & Lee, M., 2019. Changes in the early mortality of adult patients with carbapenem-resistant Acinetobacter baumannii bacteremia during 11 years at an academic medical center. Journal of infection and chemotherapy, 25(1), pp. 6–11.30342838
Cillóniz, C. ., 2016. Community-Acquired Pneumonia Due to Multidrug- and Non-Multidrug-Resistant Pseudomonas aeruginosa. Chest, 150(2), pp. 415–425.27060725
Cober, E. ., 2013. Impact of Carbapenem Resistance in Klebsiella pneumoniae Blood Stream Infection in Solid Organ Transplantation. Am J Transplant, 13(suppl 5).
Cornejo-Juárez, P. ., 2020. High mortality in an outbreak of multidrug resistant Acinetobacter baumannii infection introduced to an oncological hospital by a patient transferred from a general hospital. PloS one, 15(7).
Correa, L. ., 2013. A hospital-based matched case-control study to identify clinical outcome and risk factors associated with carbapenem-resistant Klebsiella pneumoniae infection. BMC Infect Dis., Volume 13.
Cosgrove, S. E., Kaye, K. S., Eliopoulous, G. M. & Carmeli, Y., 2002. Health and Economic Outcomes of the Emergence of Third-Generation Cephalosporin Resistance in Enterobacter Species. Arch Intern Med, Volume 162, pp. 185–190.11802752
Craig, A. P. ., 2015. The potential impact of vaccination on the prevalence of gonorrhea. Vaccine, 33(36), pp. 4520–4525.26192351
Crusio, R. ., 2014. Epidemiology and outcome of infections with carbapenem-resistant Gram-negative bacteria treated with polymyxin B-based combination therapy. Scandinavian journal of infectious diseases, 46(1), pp. 1–8.24206450
Cubero, M. ., 2015. Carbapenem-resistant and carbapenem-susceptible isogenic isolates of Klebsiella pneumoniae ST101 causing infection in a tertiary hospital. BMC Microbiology, Volume 15.
Daikos, G. ., 2009. Prospective Observational Study of the Impact of VIM-1 Metallo--Lactamase on the Outcome of Patients with Klebsiella pneumoniae Bloodstream Infections. Antimicrobial Agents and Chemotherapy, 53(5), pp. 1868–1873.19223638
Daniels, T. ., 2008. Mortality rates associated with multidrug-resistant Acinetobacter baumannii infection in surgical intensive care units. Infection control and hospital epidemiology, 29(11), pp. 1080–1083.18837670
Dantas, R., Ferreira, M., Gontijo-Filho, P. & Ribas, R., 2014. Pseudomonas aeruginosa bacteraemia: independent risk factors for mortality and impact of resistance on outcome. Journal of medical microbiology, Volume 63, pp. 1679–1687.25261066
de Gouvêa, E. ., 2012. The influence of carbapenem resistance on mortality in solid organ transplant recipients with Acinetobacter baumannii infection. BMC infectious diseases, Volume 12.
de Kraker, M. E. A. & Lipsitch, M., 2021. Burden of Antimicrobial Resistance: Compared to What?. Epidemiologic Reviews, 43(1), pp. 53–64.
de Kraker, M. ., 2011. Burden of antimicrobial resistance in European hospitals: excess mortality and length of hospital stay associated with bloodstream infections due to Escherichia coli resistant to third-generation cephalosporins. The Journal of antimicrobial chemotherapy, 66(2), pp. 398–407.21106563
de Laroche, M. ., 2021. Bloodstream infections in older population: epidemiology, outcome, and impact of multidrug resistance. European journal of clinical microbiology & infectious diseases, 40(8), pp. 1665–1672.33694038
de Souza, G. ., 2021. Carbapenem-resistant Pseudomonas aeruginosa strains: a worrying health problem in intensive care units. REVISTA DO INSTITUTO DE MEDICINA TROPICAL DE SAO PAULO, 63(0).
Deris, Z., Shafei, M. & Harun, A., 2011. Risk factors and outcomes of imipenem-resistant Acinetobacter bloodstream infection in North-Eastern Malaysia. Asian Pacific journal of tropical biomedicine, 1(4), pp. 313–315.23569782
Direk Limmathurotsakul, S. D. K. F. ., 2019. Improving the estimation of the global burden of antimicrobial resistant infections. Lancet Infect Dis, Volume 19, pp. e392–98.31427174
Djordjevic, Z. ., 2013. Risk factors for carbapenem-resistant Pseudomonas aeruginosa infection in a tertiary care hospital in Serbia. Journal of infection in developing countries, 7(9), pp. 686–690.24042106
Dunachie, S. J., Day, N. P. & Dolecek, C., 2020. The challenges of estimating the human global burden of disease of antimicrobial resistant bacteria. Current Opinion in Microbiology, Volume 57, pp. 95–101.33147565
Durham, L. K., Ge, M., Cuccia, A. & Quinn, J. P., 2010. Modeling antibiotic resistance to project future rates: quinolone resistance in Escherichia coli. European Journal of Clinical Microbiology & Infectious Diseases, Volume 29, pp. 353–356.20119677
Engler-Hüsch, S. ., 2018. In-hospital costs of community-acquired colonization with multidrug-resistant organisms at a German teaching hospital. BMC Health Services Research, 18(737).
Esterly, J. ., 2011. Impact of carbapenem resistance and receipt of active antimicrobial therapy on clinical outcomes of Acinetobacter baumannii bloodstream infections. Antimicrobial agents and chemotherapy, 55(10), pp. 4844–4849.21825287
European Centre for Disease Prevention and Control, 2020. Antimicrobial resistance in the EU/EEA (EARS-Net), Stockholm: ECDC.
European Centre for Disease Prevention and Control, 2021. About EARS-NET. [Online] Available at: https://www.ecdc.europa.eu/en/about-us/networks/disease-networks-and-laboratory-networks/ears-net-about [Accessed 4 November 2022].
Falagas, M. ., 2007. Risk factors of carbapenem-resistant Klebsiella pneumoniae infections: a matched case–control study. Journal of Antimicrobial Chemotherapy, Volume 60, pp. 1124–1130.17884829
Filice, G. A. ., 2010. Excess Costs and Utilization Associated with Methicillin Resistance for Patients with Staphylococcus aureus Infection. infection control and hospital epidemiology, 31(4), pp. 365–373.20184420
Fitzpatrick, M. ., 2016. Unique Risks and Clinical Outcomes Associated With Extended-Spectrum β-Lactamase Enterobacteriaceae in Veterans With Spinal Cord Injury or Disorder: A Case-Case-Control Study. Infection control and hospital epidemiology, 37(7), pp. 768–776.27025908
Freire, M. P. ., 2015. Carbapenem-Resistant Acinetobacter baumannii Acquired Before Liver Transplantation: Impact on Recipient Outcomes. Liver Transplantation, 22(5), pp. 615–626.
Fukuta, Y. ., 2013. Risk factors for acquisition of multidrug-resistant Acinetobacter baumannii among cancer patients. American journal of infection control, 41(12), pp. 1249–1252.23870296
Gallagher, J., Kuriakose, S., Haynes, K. & Axelrod, P., 2014. Case-case-control study of patients with carbapenem-resistant and third-generation-cephalosporin-resistant Klebsiella pneumoniae bloodstream infections. Antimicrobial agents and chemotherapy, 58(10), pp. 5732–5735.25022587
Gandra, S. ., 2019. The Mortality Burden of Multidrug-resistant Pathogens in India: A Retrospective, Observational Study. Clinical infectious diseases, 69(4), pp. 563–570.30407501
Garnica, M., Maiolino, A. & Nucci, M., 2009. Factors associated with bacteremia due to multidrug-resistant Gram-negative bacilli in hematopoietic stem cell transplant recipients. Brazilian journal of medical and biological research, 42(3), pp. 289–293.19287908
Gasink, L. B. ., 2009. Risk factors and clinical impact of Klebsiella pneumoniae carbapenemase-producing K. pneumoniae. Infect Control Hosp Epidemiol, 30(12), pp. 1180–1185.19860564
Gaviria, D. ., 2011. Carbapenem-Resistant Klebsiella pneumoniae Associated with a Long-Term-Care Facility. Morbidity and Mortality Weekly Report, 60(41), pp. 1418–1420.22012114
Gelband, H. ., 2015. The State of the World’s Antibiotics 2015. Wound Healing Southern Africa, 8(2), pp. 30–34.
Ghafur, A., Vidyalakshmi, P., Kannaian, P. & Balasubramaniam, R., 2014. Clinical study of carbapenem sensitive and resistant Gram-negative bacteremia in neutropenic and nonneutropenic patients: The first series from India. Indian journal of cancer, 51(4), pp. 453–455.26842159
Giannella, M. ., 2015. Risk Factors for Infection With Carbapenem-Resistant Klebsiella pneumoniae After Liver Transplantation: The Importance of Pre- and Posttransplant. American Journal of Transplantation, Volume 15, pp. 1708–1715.25754742
Goldstein, E. ., 2019. Antimicrobial resistance prevalence, rates of hospitalization with septicemia and rates of mortality with sepsis in adults in different US states. International Journal of Antimicrobial Agents, Volume 54, pp. 23–34.30851403
Gudiol, C. ., 2011. Bacteraemia due to multidrug-resistant Gram-negative bacilli in cancer patients: risk factors, antibiotic therapy and outcomes. The Journal of antimicrobial chemotherapy, 66(3), pp. 657–663.21193475
Guh, A. Y. ., 2020. Trends in U.S. Burden of Clostridioides difficile Infection and Outcomes. N Engl J Med, Volume 382, pp. 1320–1330.32242357
Guo, N. ., 2016. Risk factors and outcomes of hospitalized patients with blood infections caused by multidrug-resistant Acinetobacter baumannii complex in a hospital of Northern China. American journal of infection control, 44(4), pp. e37–39.26804303
Gupta, V. ., 2019. National prevalence estimates for resistant Enterobacteriaceae and Acinetobacter species in hospitalized patients in the United States. International Journal of Infectious Diseases, Volume 85, pp. 203–211.31229615
Hauck, C. ., 2016. Spectrum of Excess Mortality due to Carbapenem-Resistant Klebsiella pneumoniae Infections. Clin Microbiol Infect., 22(6), pp. 513–519.26850824
Henig, O. ., 2015. Risk factors for and impact of carbapenem-resistant Acinetobacter baumannii colonization and infection: matched case-control study. European journal of clinical microbiology & infectious diseases, 34(10), pp. 2063–2068.26205665
Hoxha, A. ., 2016. Attributable mortality of carbapenem-resistant Klebsiella pneumoniae infections in a prospective matched cohort study in Italy, 2012–2013. The Journal of Hospital Infection, 92(1), pp. 61–66.26319590
Hristea, A. ., 2011. Gram negative bacterial bloodstream infections: resistance patterns and risk factors. REVISTA ROMANA DE MEDICINA DE LABORATOR, 19(3), pp. 241–249.
Huang, S. ., 2012. Risk factors and clinical outcomes of patients with carbapenem-resistant Acinetobacter baumannii bacteremia. Journal of microbiology, immunology, and infection, 45(5), pp. 356–362.
Huang, S., Liu, M., Lin, C. & Shi, Z., 2014. Molecular surveillance and clinical outcomes of carbapenem-resistant Escherichia coli and Klebsiella pneumoniae infections. Journal of microbiology, immunology, and infection, 47(3), pp. 187–196.
Huang, Y., Wu, P., Lin, Y. & Wang, F., 2019. Comparison of clinical characteristics of bacteremia from Elizabethkingia meningoseptica and other carbapenem-resistant, non-fermenting Gram-negative bacilli at a tertiary medical center. Journal of microbiology, immunology, and infection, 52(2), pp. 304–311.
Humphries, R. M. ., 2017. Carbapenem-Resistant Enterobacteriaceae Detection Practices in California: What Are We Missing?. Clinical Infectious Diseases, pp. 1061–7.
Hussein, K. ., 2013. Impact of carbapenem resistance on the outcome of patients’ hospital-acquired bacteraemia caused by Klebsiella pneumoniae. The Journal of Hospital Infection, 83(4), pp. 307–313.23313086
Hu, Y. ., 2016. A retrospective study of risk factors for carbapenem-resistant Klebsiella pneumoniae acquisition among ICU patients. The Journal of Infection in Developing Countries, 10(3).
Jamulitrat, S., Arunpan, P. & Phainuphong, P., 2009. Attributable mortality of imipenem-resistant nosocomial Acinetobacter baumannii bloodstream infection. Journal of the Medical Association of Thailand, 92(3), pp. 413–419.19301737
Jeong, S. ., 2014. Risk factors for mortality in patients with bloodstream infections caused by carbapenem-resistant Pseudomonas aeruginosa: clinical impact of bacterial virulence and strains on outcome. Diagnostic microbiology and infectious disease, 80(2), pp. 130–135.25112900
Joo, E. ., 2011. Risk factors for mortality in patients with Pseudomonas aeruginosa bacteremia: clinical impact of antimicrobial resistance on outcome. Microbial drug resistance, 17(2), pp. 305–312.21381966
Kadri, S. ., 2018. Difficult-to-Treat Resistance in Gram-negative Bacteremia at 173 US Hospitals: Retrospective Cohort Analysis of Prevalence, Predictors, and Outcome of Resistance to All First-line Agents. Clinical infectious diseases, 67(12), pp. 1803–1814.30052813
Kadri, S. S. ., 2019. Attributable Mortality from Extensively Drug Resistant GramNegative Infections Using Propensity-matched Tracer Antibiotic. Am J Infect Control, 47(9), pp. 1040–1047.30824387
Kang, C. ., 2012. Risk factors for infection and treatment outcome of extended-spectrum β-lactamase-producing Escherichia coli and Klebsiella pneumoniae bacteremia in patients with hematologic malignancy. Annals of hematology, 91(1), pp. 115–121.21556875
Karve, S. ., 2018. The impact of initial antibiotic treatment failure: Real-world insights in patients with complicated urinary tract infection. The Journal of infection, 76(2), pp. 121–131.29128389
Khairy, R., Mahmoud, M., Shady, R. & Esmail, M., 2020. Multidrug-resistant Klebsiella pneumoniae in hospital-acquired infections: Concomitant analysis of antimicrobial resistant strains. International journal of clinical practice, 74(4).
Kim, S. ., 2012. Risk factors for occurrence and 30-day mortality for carbapenem-resistant Acinetobacter baumannii bacteremia in an intensive care unit. Journal of Korean medical science, 27(8), pp. 939–947.22876063
Kim, Y. ., 2018. Carbapenem-resistant Acinetobacter baumannii Bacteremia in Liver Transplant Recipients. Transplantation Proceedings, Volume 50, pp. 1132–1135.29731080
Kumar, S. ., 2018. Healthcare-Associated Pneumonia and Hospital-Acquired Pneumonia: Bacterial Aetiology, Antibiotic Resistance and Treatment Outcomes: A Study From North India. Lung, 196(4), pp. 469–479.29691645
Kuo, L. ., 2007. Multidrug-resistant Acinetobacter baumannii bacteraemia: clinical features, antimicrobial therapy and outcome. Clinical microbiology and infection, 13(2), pp. 196–198.17328733
Lee, N. ., 2007. Clinical and economic impact of multidrug resistance in nosocomial Acinetobacter baumannii bacteremia. Infection control and hospital epidemiology, 28(6), pp. 713–719.17520546
Lee, X. ., 2021. Attributable Length of Stay, Mortality Risk, and Costs of Bacterial Health Care-Associated Infections in Australia: A Retrospective Case-cohort Study. Clinical Infectious Diseases, 72(10), pp. e506–514.32822465
Lemos, E. ., 2014. Impact of carbapenem resistance on clinical and economic outcomes among patients with Acinetobacter baumannii infection in Colombia. Clinical microbiology and infection, 20(2), pp. 174–180.23668595
Lessa, F. C. ., 2015. Burden of Clostridium difficile Infection in the United States. New England Journal of Medicine, 372(9), pp. 825–834.25714160
Li, D. ., 2014. Risk factors for hospital-acquired bloodstream infections caused by extended-spectrum β-lactamase Klebsiella pneumoniae among cancer patients. Irish journal of medical science, 183(3), pp. 463–469.24293294
Lin, K., Lauderdale, T., Wang, J. & Chang, S., 2016. Carbapenem-resistant Pseudomonas aeruginosa in Taiwan: Prevalence, risk factors, and impact on outcome of infections. Journal of microbiology, immunology, and infection, 49(1), pp. 52–59.
Lin, W. ., 2019. Prevalence of and risk factor for community-onset third-generation cephalosporin-resistant Escherichia coli bacteremia at a medical center in Taiwan. BMC infectious diseases, 19(1).
Liu, C. ., 2016. Risk factors of mortality in patients with carbapenem-resistant Acinetobacter baumannii bacteremia. Journal of microbiology, immunology, and infection, 49(6), pp. 934–940.
Liu, J. ., 2020. Culture-Positive Spontaneous Ascitic Infection in Patients with Acute Decompensated Cirrhosis: Multidrug-Resistant Pathogens and Antibiotic Strategies.. Yonsei medical journal, 61(2), pp. 145–153.31997623
Liu, Q. ., 2015. Risk and Prognostic Factors for Multidrug-Resistant Acinetobacter Baumannii Complex Bacteremia: A Retrospective Study in a Tertiary Hospital of West China. PloS one, 10(6).
Liu, S. ., 2012. Outcomes and characteristics of ertapenem-nonsusceptible Klebsiella pneumoniae bacteremia at a university hospital in Northern Taiwan: A matched case-control study. Journal of Microbiology, Immunology and Infection, 45(2), pp. 113–119.
Liu, Y. ., 2020. Prospective multi-center evaluation on risk factors, clinical characteristics and outcomes due to carbapenem resistance in Acinetobacter baumannii complex bacteraemia: experience from the Chinese Antimicrobial Resistance Surveillance of Nosocomial Infect. Journal of medical microbiology, 69(7), pp. 949–959.32584215
Lopez-Lozano, J.-M. ., 2000. Modelling and forecasting antimicrobial resistance and its dynamic relationship to antimicrobial use: a time series analysis. International Journal of Antimicrobial Agents, Volume 14, pp. 21–31.10717497
Lu, Q. ., 2012. Efficacy of high-dose nebulized colistin in ventilator-associated pneumonia caused by multidrug-resistant Pseudomonas aeruginosa and Acinetobacter baumannii. Anesthesiology, 117(6), pp. 1335–1347.23132092
Luyt, C. ., 2014. Imipenem, meropenem, or doripenem to treat patients with Pseudomonas aeruginosa ventilator-associated pneumonia. Antimicrobial agents and chemotherapy, 58(3), pp. 1372–1380.24342638
MacVane, S. H., Tuttle, L. O. & Nicolau, D. P., 2014. Impact of extended-spectrum β-lactamase–producing organisms on clinical and economic outcomes in patients with urinary tract infection. Journal of hospital medicine, 9(4), pp. 232–238.24464783
Majangara, R., Gidiri, M. & Chirenje, Z., 2018. Microbiology and clinical outcomes of puerperal sepsis: a prospective cohort study. Journal of obstetrics and gynaecology, 38(5), pp. 635–641.29447024
Marazzi, A., Paccaud, F., Ruffieux, C. & Beguin, C., 1998. Fitting the Distributions of Length of Stay by Parametric Models. Medical Care, 36(6), pp. 915–927.9630132
Marchaim, D. ., 2011. Outcomes and genetic relatedness of carbapenem-resistant enterobacteriaceae at Detroit medical center. Infection control and hospital epidemiology, 32(9), pp. 861–871.21828966
Mark, D. ., 2021. Third-Generation Cephalosporin Resistance and Associated Discordant Antibiotic Treatment in Emergency Department Febrile Urinary Tract Infections. Annals of emergency medicine, 78(3), pp. 357–369.33781606
Martelius, T. ., 2016. Nosocomial bloodstream infections caused by Escherichia coli and Klebsiella pneumoniae resistant to third-generation cephalosporins, Finland, 1999-2013: Trends, patient characteristics and mortality. Infectious diseases, 48(3), pp. 229–234.26577519
Maruo, K. & Berven, S. H., 2014. Outcome and treatment of postoperative spine surgical site infections: predictors of treatment success and failure. Journal of Orthopaedic Science, 19(3), pp. 398–404.24510397
Mauldin, P. ., 2010. Attributable hospital cost and length of stay associated with health care-associated infections caused by antibiotic-resistant gram-negative bacteria. Antimicrobial agents and chemotherapy, 54(1), pp. 109–115.19841152
Meng, X. ., 2017. Risk factors and medical costs for healthcare-associated carbapenem-resistant Escherichia coli infection among hospitalized patients in a Chinese teaching hospital.. BMC infectious diseases, 17(1).
Meradji, S. ., 2015. Epidemiology of carbapenem non-susceptible Pseudomonas aeruginosa isolates in Eastern Algeria. Antimicrobial resistance and infection control, Volume 4.
Micek, S. ., 2015. An international multicenter retrospective study of Pseudomonas aeruginosa nosocomial pneumonia: impact of multidrug resistance. Critical care, 19(1).
Michaelidis, C. I. ., 2016. The hidden societal cost of antibiotic resistance per antibiotic prescribed in the United States: an exploratory analysis. BMC Infectious Diseases, 16(655).
Michalopoulos, A. ., 2011. Epidemiologic, clinical characteristics, and risk factors for adverse outcome in multiresistant gram-negative primary bacteremia of critically ill patients. American journal of infection control, 39(5), pp. 396–400.21035919
Monnet, D. L. ., 2001. Making sense of antimicrobial use and resistance surveillance data: application of ARIMA and transfer function models. Clinical Microbiology and Infection, 7(Supplement 5), pp. 29–36.11990680
Morales, E. ., 2012. Hospital costs of nosocomial multi-drug resistant Pseudomonas aeruginosa acquisition. BMC Health Services Research, 12(122).
Morata, L. ., 2012. Influence of multidrug resistance and appropriate empirical therapy on the 30-day mortality rate of Pseudomonas aeruginosa bacteremia. Antimicrobial agents and chemotherapy, 56(9), pp. 4833–4837.22751533
Mosqueda-Gómez, J. ., 2008. Molecular epidemiology and risk factors of bloodstream infections caused by extended-spectrum beta-lactamase-producing Klebsiella pneumoniae A case-control study. International journal of infectious diseases, 12(6), pp. 653–659.18511321
Mouloudi, E. ., 2010. Bloodstream infections caused by metallo-β-lactamase/Klebsiella pneumoniae carbapenemase-producing K. pneumoniae among intensive care unit patients in Greece: risk factors for infection and impact of type of resistance on outcomes. Infect Control Hosp Epidemiol., 31(12), pp. 1250–1256.20973725
Munoz-Price, L. ., 2010. Clinical outcomes of carbapenem-resistant Acinetobacter baumannii bloodstream infections: study of a 2-state monoclonal outbreak. Infection control and hospital epidemiology, 31(10), pp. 1057–1062.20715975
Murray, e. a., 2022. Global burden of bacterial antimicrobial resistance in 2019: a systematic analysis. The Lancet, Volume 399, pp. 629–655.
Naylor, N. R. ., 2018. Estimating the burden of antimicrobial resistance: a systematic literature review. Antimicrobial Resistance and Infection Control, 7(58), pp. 1–17.29312658
Naylor, N. R. ., 2019. The health and cost burden of antibiotic resistant and susceptible Escherichia coli bacteraemia in the English hospital setting: A national retrospective cohort study. PLoS ONE, 14(9).
Neidell, M. J. ., 2012. Costs of healthcare-and community-associated infections with antimicrobial-resistant versus antimicrobial-susceptible organisms. Clinical Infectious Diseases, 55(6), pp. 807–815.22700828
Nelson, R. E. N. S. D. ., 2015. The Magnitude of Time-Dependent Bias in the Estimation of Excess Length of Stay Attributable to Healthcare-Associated Infections. Infect. Control Hosp. Epidemiol., 36(9), pp. 1089–1094.26041436
Nelson, R. ., 2021. National Estimates of Healthcare Costs Associated With Multidrug-Resistant Bacterial Infections Among Hospitalized Patients in the United States. Clin Infect Dis, 29(72(Suppl 1)), pp. S17–S26.
Nemeth, J. ., 2012. Multidrug-resistant bacteria in travellers hospitalized abroad: prevalence, characteristics, and influence on clinical outcome. The Journal of hospital infection, 82(4), pp. 254–259.23103249
Nikolaou, M. & Tam, V. H., 2006. A new modeling approach to the effect of antimicrobial agents on heterogeneous microbial populations. Journal of mathematical biology, 52(2), pp. 154–182.16195922
Ning, C. ., 2019. Adverse clinical outcomes associated with multidrug-resistant organisms in patients with infected pancreatic necrosis. Pancreatology, 19(7), pp. 935–940.31558390
Nutman, A. ., 2014. A case-control study to identify predictors of 14-day mortality following carbapenem-resistant Acinetobacter baumannii bacteraemia. Clinical microbiology and infection, 20(12).
Ny, P., Nieberg, P. & Wong-Beringer, A., 2015. Impact of carbapenem resistance on epidemiology and outcomes of nonbacteremic Klebsiella pneumoniae infections. Am J Infect Control, 43(10), pp. 1076–1080.26190386
Orsi, G. ., 2013. Patient risk factors for outer membrane permeability and KPC-producing carbapenem-resistant Klebsiella pneumoniae isolation: results of a double case–control study. Infection, Volume 41, pp. 61–67.23070604
Orsi, G. ., 2011. Risk factors and clinical significance of ertapenem-resistant Klebsiella pneumoniae in hospitalised patients. J Hosp Infect, 78(1), pp. 54–58.21450365
Ortega, M. ., 2009. Analysis of 4758 Escherichia coli bacteraemia episodes: predictive factors for isolation of an antibiotic-resistant strain and their impact on the outcome. The Journal of antimicrobial chemotherapy, 63(3), pp. 568–574.19126669
Pan, F. ., 2019. Fecal carriage and molecular epidemiology of carbapenem-resistant Enterobacteriaceae from outpatient children in Shanghai. BMC Infectious Diseases, Volume 19.
Pang, F., Jia, X., Zhao, Q. & Zhang, Y., 2018. Factors associated to prevalence and treatment of carbapenem-resistant Enterobacteriaceae infections: a seven years retrospective study in three tertiary care hospitals.. Annals of clinical microbiology and antimicrobials, 17(1).
Papadimitriou-Olivgeris, M. ., 2019. Risk factors for acute kidney injury in critically ill patients with bacteraemia by carbapenem non-susceptible Gram negative bacteria. Le infezioni in medicina, 27(4), pp. 380–392.31846987
Papadimitriou-Olivgeris, M. ., 2017. Risk factors and predictors of carbapenem-resistant Pseudomonas aeruginosa and Acinetobacter baumannii mortality in critically ill bacteraemic patients over a 6-year period (2010-15): antibiotics do matter. Journal of medical microbiology, 66(8), pp. 1092–1101.28758623
Parveen, A. ., 2015. Bacteraemia caused by Escherichia coli in cancer patients at a specialist center in Pakistan. The Journal of the Pakistan Medical Association, 65(12), pp. 1271–1276.26627506
Patel, G. ., 2008. Outcomes of carbapenem-resistant Klebsiella pneumoniae infection and the impact of antimicrobial and adjunctive therapies. Infect Control Hosp Epidemiol, 29(12), pp. 1099–1106.18973455
Peña, C. ., 2013. Impact of multidrug resistance on Pseudomonas aeruginosa ventilator-associated pneumonia outcome: predictors of early and crude mortality. European journal of clinical microbiology & infectious diseases, 32(3), pp. 413–420.23344827
Peña, C. ., 2012. Prospective multicenter study of the impact of carbapenem resistance on mortality in Pseudomonas aeruginosa bloodstream infections. Antimicrobial agents and chemotherapy, 56(3), pp. 1265–1272.22155832
Peng, Y. ., 2014. Multidrug-resistant Pseudomonas aeruginosa infections pose growing threat to health care-associated infection control in the hospitals of Southern China: a case-control surveillance study. American journal of infection control, 42(12), pp. 1308–1311.25444305
Peralta, G. ., 2007. Impact of antibiotic resistance and of adequate empirical antibiotic treatment in the prognosis of patients with Escherichia coli bacteraemia. The Journal of antimicrobial chemotherapy, 60(4), pp. 855–863.17644532
Pessoa-Silva, C. L., 2020. GLobal Antimicrobial Resistance and Use Surveillance System. s.l.:s.n.
Pezzani, M. D. ., 2021. Methodological quality of studies evaluating the burden of drug-resistant infections in humans due to the WHO Global Antimicrobial Resistance Surveillance System target bacteria. Clinical Microbiology and Infection, 27(5), pp. 687–696.33450389
Picot-Guéraud, R. ., 2015. Bacteremia caused by multidrug-resistant bacteria in a French university hospital center: 3 years of collection. American journal of infection control, 43(9), pp. 960–964.26082260
Pierri, M. ., 2016. Risk Factors and Impact on Clinical Outcome of Multidrug-Resistant Acinetobacter Baumannii Acquisition in Cardiac Surgery Patients. Journal of cardiothoracic and vascular anesthesia, 30(3), pp. 680–686.26718661
Pouch, S. M. ., 2015. Epidemiology and outcomes of carbapenem-resistant Klebsiella pneumoniae bacteriuria in kidney transplant recipients. Transpl Infect Dis, 17(6), pp. 800–809.26341757
Pouwels, K. B. ., 2020. Estimating the Effect of Healthcare-Associated Infections on Excess Length of Hospital Stay Using Inverse Probability–Weighted Survival Curves. Clinical Infectious Diseases, 71(9), pp. 415–420.31676905
Prata-Rocha, M., Gontijo-Filho, P. & Melo, G., 2012. Factors influencing survival in patients with multidrug-resistant Acinetobacter baumannii infection. The Brazilian journal of infectious diseases, 16(3), pp. 237–241.22729190
Prates, C. ., 2011. Risk factors for 30-day mortality in patients with carbapenem-resistant Acinetobacter baumannii during an outbreak in an intensive care unit. Epidemiology and infection, 139(3), pp. 411–418.20513254
Roberts, R. R. ., 2009. Hospital and Societal Costs of Antimicrobial-Resistant Infections in a Chicago Teaching Hospital: Implications for Antibiotic Stewardship. Clinical Infectious Diseases, Volume 49, pp. 1175–84.19739972
Rodríguez-Baño, J. ., 2010. Community-onset bacteremia due to extended-spectrum beta-lactamase-producing Escherichia coli: risk factors and prognosis. Clinical infectious diseases, 50(1), pp. 40–48.19995215
Rossi, G. I. ., 2017. Carbapenem-resistant Pseudomonas aeruginosa: association with virulence genes and biofilm formation. Brazilian journal of microbiology, 48(2), pp. 211–217.28034598
Rossi, I. ., 2019. Incidence of infections caused by carbapenem-resistant Acinetobacter baumannii. American Journal of Infection Control, Volume 47, pp. 1431–1435.31399285
Routsi, C. ., 2010. Carbapenem-resistant versus carbapenem-susceptible Acinetobacter baumannii bacteremia in a Greek intensive care unit: risk factors, clinical features and outcomes. Infection, 38(3), pp. 173–180.20224962
Rueda, V. & Tobón, J., 2014. Risk factors for infection with carbapenem-resistant Klebsiella pneumoniae: a case-case-control study. Colomb Med (Cali), 45(2), pp. 54–60.25100889
Schwaber, M. ., 2008. Predictors of carbapenem-resistant Klebsiella pneumoniae acquisition among hospitalized adults and effect of acquisition on mortality. Antimicrob Agents Chemother, 52(3), pp. 1028–1033.18086836
Seboxa, T. ., 2015. High Mortality from Blood Stream Infection in Addis Ababa, Ethiopia, Is Due to Antimicrobial Resistance. PloS one, 10(12).
Serra-Burriel, M. ., 2020. Impact of multi-drug resistant bacteria on economic and clinical outcomes of healthcare-associated infections in adults: Systematic review and meta-analysis. PLoS ONE, 15(1).
Sheng, W. ., 2010. A multicenter study of risk factors and outcome of hospitalized patients with infections due to carbapenem-resistant Acinetobacter baumannii.. International journal of infectious diseases, 14(9), pp. e764–769.20646946
Shrestha, P. ., 2018. Enumerating the economic cost of antimicrobial resistance per antibiotic consumed to inform the evaluation of interventions affecting their use. Antimicrobial Resistance and Infection Control, 7(98).
Simkins, J., Muggia, V., Cohen, H. W. & Minamoto, G. Y., 2014. Carbapenem-resistant Klebsiella pneumoniae infections in kidney transplant recipients: a case-control study. Transpl Infect Dis, 16(5), pp. 775–782.25092500
Siwakoti, S. ., 2018. Incidence and outcomes of multidrug-resistant gram-negative bacteria infections in intensive care unit from Nepal- a prospective cohort study. Antimicrobial resistance and infection control, Volume 7, p. 114.30275945
Smith, R. & Coast, J., 2012. The economic burden of antimicrobial resistance: Why it is more serious than current studies suggest, London: London School of Hygiene & Tropical Medicine.
Smith, R. D., Yago, M., Millar, M. & Coast, J., 2006. A Macroeconomic Approach to Evaluating Policies to Contain Antimicrobial Resistance: A Case Study of Methicillin-Resistant Staphylococcus aureus (MRSA). Applied Health and Economic Policy, 5(1), pp. 55–65.
Song, J. ., 2011. Clinical and microbiological characterization of carbapenem-resistant Acinetobacter baumannii bloodstream infections. Journal of medical microbiology, 60(0), pp. 605–611.21233298
Song, K. ., 2009. Clinical outcomes of spontaneous bacterial peritonitis due to extended-spectrum beta-lactamase-producing Escherichia coli and Klebsiella species: a retrospective matched case-control study. BMC infectious diseases, Volume 9.
Soucy, J.-P.R. ., 2019. Joint modeling of resistance to six antimicrobials in urinary Escherichia coli isolates in Quebec, Canada. Antimicrobial Agents and Chemotherapy, Volume 63, pp. e02531–18.31010864
Suárez, C. ., 2010. Influence of carbapenem resistance on mortality and the dynamics of mortality in Pseudomonas aeruginosa bloodstream infection. International journal of infectious diseases, Volume 14, pp. e73–78.
Superti, S., Augusti, G. & Zavascki, A., 2009. Risk factors for and mortality of extended-spectrum-beta-lactamase-producing Klebsiella pneumoniae and Escherichia coli nosocomial bloodstream infections. Revista do Instituto de Medicina Tropical de Sao Paulo, 51(4), pp. 211–216.19739001
Su, T. ., 2015. Clinical characteristics and risk factors for mortality in cefepime-resistant Pseudomonas aeruginosa bacteremia. Journal of microbiology, immunology, and infection, 48(2), pp. 175–182.
Suzuki, H. ., 2019. Attributable mortality due to fluoroquinolone and extended-spectrum cephalosporin resistance in hospital-onset Escherichia coli and Klebsiella spp bacteremia: A matched cohort study in 129 Veterans Health Administration medical centers.. Infection control and hospital epidemiology, 40(8), pp. 928–931.31196237
Taheri, P. A., Butz, D. A. & Greenfield, L. J., 2000. Length of Stay Has Minimal Impact on the Cost of Hospital Admission. J Am Coll Surg, pp. 123–130.10945354
Tam, V. ., 2010. Impact of multidrug-resistant Pseudomonas aeruginosa bacteremia on patient outcomes. Antimicrobial agents and chemotherapy, 54(9), pp. 3717–3722.20585122
Taylor, J. ., 2014. Estimating the economic costs of antimicrobial resistance: Model and Results, Santa Monica: RAND Corporation.
Teillant, A. ., 2015. Potential burden of antibiotic resistance on surgery and cancer chemotherapy antibiotic prophylaxis in the USA: a literature review and modelling study. The Lancet, 15(12), pp. 1429–1437.26482597
Thaden, J. ., 2017. Increased Costs Associated with Bloodstream Infections Caused by Multidrug-Resistant Gram-Negative Bacteria Are Due Primarily to Patients with Hospital-Acquired Infections. Antimicrobial Agents and Chemotherapy, 61(3), pp. e01709–16.27993852
Thorpe, K. E., Joski, P. & Johnston, K. J., 2018. Antibiotic-Resistant Infection Treatment Costs Have Doubled Since 2002, Now Exceeding $2 Billion Annually. Pharmaceuticals & Medical Technology, 37(4).
Tofas, P. ., 2017. Pseudomonas aeruginosa bacteraemia in patients with hematologic malignancies: risk factors, treatment and outcome. Diagnostic microbiology and infectious disease, 88(4), pp. 335–341.28529091
Trecarichi, E. ., 2019. Bloodstream infections caused by Escherichia coli in onco-haematological patients: Risk factors and mortality in an Italian prospective survey. PloS one, 14(10).
Trecarichi, E. ., 2011. Multidrug resistant Pseudomonas aeruginosa bloodstream infection in adult patients with hematologic malignancies. Haematologica, 96(1), pp. e1–3.21193424
Trottier, V. ., 2007. Outcomes of Acinetobacter baumannii infection in critically ill burned patients. Journal of burn care & research, 28(2), pp. 248–254.17351441
Tseng, W. ., 2018. Risk for subsequent infection and mortality after hospitalization among patients with multidrug-resistant gram-negative bacteria colonization or infection. Antimicrobial resistance and infection control, Volume 7, p. 93.30083312
Tsui, K. ., 2012. Laboratory identification, risk factors, and clinical outcomes of patients with bacteremia due to Escherichia coli and Klebsiella pneumoniae producing extended-spectrum and AmpC type β-lactamases. Journal of microbiology, immunology, and infection, 45(3), pp. 193–199.
Tu, B. ., 2020. Microbiological Characteristics and Antibiotic Sensitivity in Patients with Nosocomial Spontaneous Bacterial Peritonitis Caused by Escherichia coli: A Multicenter Study. INFECTIOUS MICROBES & DISEASES, 2(4), pp. 167–172.38630105
Tumbarello, M. ., 2020. Characterisation and risk factor profiling of Pseudomonas aeruginosa urinary tract infections: pinpointing those likely to be caused by multidrug-resistant strains.. International journal of antimicrobial agents, 55(4).
Tumbarello, M. ., 2011. Multidrug-resistant Pseudomonas aeruginosa bloodstream infections: risk factors and mortality. Epidemiology and infection, 139(11), pp. 1740–1749.21226988
Tuon, F., Gortz, L. & Rocha, J., 2012. Risk factors for pan-resistant Pseudomonas aeruginosa bacteremia and the adequacy of antibiotic therapy. The Brazilian journal of infectious diseases, 16(4), pp. 351–356.22846123
Tuon, F. ., 2017. Risk factors for mortality in patients with ventilator-associated pneumonia caused by carbapenem-resistant Enterobacteriaceae. The Brazilian journal of infectious diseases, 21(1), pp. 1–6.27821248
Ulu, A. ., 2015. Risk Factors of Carbapenem-Resistant Klebsiella pneumoniae Infection: A Serious Threat in ICUs. Med Sci Monit, Volume 21, pp. 219–224.25595166
van der Starre, W. ., 2011. Risk factors for fluoroquinolone-resistant Escherichia coli in adults with community-onset febrile urinary tract infection. The Journal of antimicrobial chemotherapy, 66(3), pp. 650–656.21123286
van Duin, D. & Paterson, D., 2016. Multidrug Resistant Bacteria in the Community: Trends and Lessons Learned. Infectious Disease Clinics of North America, June, 30(2), pp. 377–390.27208764
Vardakas, K. ., 2015. Characteristics, risk factors and outcomes of carbapenem-resistant Klebsiella pneumoniae infections in the intensive care unit. J. Infect., 70(6), pp. 592–599.25447713
Vargas-Alzate, C. ., 2018. High excess costs of infections caused by carbapenem-resistant Gram-negative bacilli in an endemic region. International journal of antimicrobial agents, 51(4), pp. 601–607.29277527
Wang, Z., Qin, R., Huang, L. & Sun, L., 2018. Risk Factors for Carbapenem-resistant Klebsiella pneumoniae Infection and Mortality of Klebsiella pneumoniae Infection. Chin Med J, 131(1), pp. 56–62.29271381
Willmann, M. ., 2013. Time Series Analysis as a Tool To Predict the Impact of Antimicrobial Restriction in Antibiotic Stewardship Programs Using the Example of Multidrug-Resistant Pseudomonas aeruginosa. Antimicrobial Agents and Chemotherapy, April, 57(4), pp. 1797–1803.23380719
World Health Organization Regional Office for Europe, 2021. Central Asian and European Surveillance of Antimicrobial Resistance (CAESAR). [Online] Available at: https://www.euro.who.int/en/health-topics/disease-prevention/antimicrobial-resistance/surveillance/central-asian-and-european-surveillance-of-antimicrobial-resistance-caesar
World Health Organization, 2021. Global Antimicrobial Resistance and Use Surveillance System (GLASS). [Online] Available at: https://www.who.int/initiatives/glass [Accessed 30 July 2021].
Wozniak, T. M., Barnsbee, L., Lee, X. J. & Pacella, R. E., 2019. Using the best available data to estimate the cost of antimicrobial resistance: a systematic review. Antimicrobial Resistance and Infection Control, 8(26).
Yang, Y. ., 2013. Comparison between bacteremia caused by carbapenem resistant Acinetobacter baumannii and Acinetobacter nosocomialis. BMC infectious diseases, Volume 13.
Zhang, D. ., 2018. Risk factors for carbapenem-resistant Pseudomonas aeruginosa infection or colonization in a Chinese teaching hospital. Journal of infection in developing countries, 12(8), pp. 642–648.31958327
Zhang, Y. ., 2020. Risk Factors for Mortality of Inpatients with Pseudomonas aeruginosa Bacteremia in China: Impact of Resistance Profile in the Mortality. Infection and drug resistance, Volume 13, pp. 4115–4123.33209041
Zhao, S. ., 2021. Epidemiology of and risk factors for mortality due to carbapenemase-producing organisms (CPO) in healthcare facilities. The Journal of hospital infection, Volume 110, pp. 184–193.33571557
Zhao, Y. ., 2020. Risk Factors and Outcomes of Antibiotic-resistant Pseudomonas aeruginosa Bloodstream Infection in Adult Patients With Acute Leukemia. Clinical infectious diseases, Volume 71, pp. 386–393.
Zheng, Y. ., 2013. Risk factors and mortality of patients with nosocomial carbapenem-resistant Acinetobacter baumannii pneumonia. American journal of infection control, 41(7).
Zhen, X. ., 2020. Clinical and Economic Impact of Third-Generation Cephalosporin-Resistant Infection or Colonization Caused by Escherichia coli and Klebsiella pneumoniae: A Multicenter Study in China.. International journal of environmental research and public health, 17(24).
Zhong, L. ., 2012. Multidrug-resistant gram-negative bacterial infections after liver transplantation - spectrum and risk factors. The Journal of Infection, 64(3), pp. 299–310.22198738
Zhou, H. ., 2019. Risk factors for acquisition and mortality of multidrug-resistant Acinetobacter baumannii bacteremia: A retrospective study from a Chinese hospital. Medicine, 98(13).
Zimlichman, E. ., 2013. Health care–associated infections: a meta-analysis of costs and financial impact on the US health care system. JAMA internal medicine, 173(22), pp. 2039–2046.23999949