# ACKNOWLEDGMENTS

We gratefully acknowledge Casey Sullivan (ASPE) and Amber Jessup (formerly at ASPE) for their leadership, guidance, and input to this study. We also would like to thank members of the Project Advisory Group at the U.S. Department of Health and Human Services (HHS): John Farley, Thushi Amini, James Byrne, Michael L. Lanthier, Ramya Gopinath, Dmitri Iarikov, Gilbert “Lynn” Marks (formerly at HHS), Tyler Merkeley (formerly at HHS), Elizabeth O’Shaughnessy, Sameer S. Kadri-Rodriguez, Jeffrey Strich, Christopher Houchens, Mark Albrecht, Jessica Swenson, Sue Cammarata, Alan (Laurence) Carr, Michael R. Craig, John A. Jernigan, Dawn M. Sievert, Shelley Magill, Doug Scott, Stephen Murphy, Trinidad Beleche, Allison Kolbe, Erin Rubens (formerly at HHS), Aaron Kearsley, Sharon Arnold, Stephen Murphy, and Jessica Marus.