# EXECUTIVE SUMMARY

It is well known that antimicrobial resistance (AMR) creates a substantial and ongoing public health and economic burden and understanding the size and nature of this burden is important for the ability to respond to the threat of AMR. However, estimating or projecting that burden within the U.S. is a difficult task that prompts a variety of assumptions and produces conflicting results, making it challenging for researchers and policymakers to interpret and act upon that data.^1^ To better understand the issues that complicate efforts to model the current and future AMR burden in the U.S., we conducted a systematic literature review of the 15 combinations of pathogen and drug resistance (shown in Table ES - 1), nearly all of which were designated serious or urgent threats by CDC in its report Antibiotic Resistance Threats in the United States, 2019 (CDC, 2019). The pathogens spanned Klebsiella pneumoniae (K. pneumoniae), Acinetobacter baumannii (A. baumannii), Enterobacter aerogenes/Enterobacter cloacae (E. aerogenes/E. cloacae)^2^, Escherichia coli (E. coli), and Pseudomonas aeruginosa (P. aeruginosa).^3^ The drug resistance phenotypes included multi-drug resistance, carbapenem resistance, third-generation cephalosporin resistance, and fluoroquinolone resistance. Table ES - 1 presents the fifteen pathogen-drug combinations we studied and the number of studies we included, categorized by region (U.S., Europe, and Other).

Table ES - 1 Number of Studies from Each Region, by Pathogen-Drug Combination

Drug Resistance | Pathogen | U.S. | Europe | Other
Carbapenem | A. baumannii | 3 | 2 | 23
Multi-Drug Resistant (MDR) | A. baumannii | 4 | 1 | 11
Carbapenem | E. coli | 2 | 0 | 6
Third-Generation Cephalosporin | E. coli | 2 | 3 | 7
Fluoroquinolone | E. coli | 4 | 2 | 0
MDR | E. coli | 1 | 6 | 5
Carbapenem | E. aerogenes/E. cloacae | 0 | 1 | 3
MDR | E. aerogenes/E. cloacae | 0 | 0 | 1
Carbapenem | K. pneumoniae | 11 | 10 | 9
Third-Generation Cephalosporin | K. pneumoniae | 3 | 1 | 8
Fluoroquinolone-Resistant | K. pneumoniae | 3 | 0 | 0
MDR | K. pneumoniae | 0 | 1 | 8
Carbapenem-Resistant | P. aeruginosa | 2 | 6 | 13
Third-Generation Cephalosporin | P. aeruginosa | 1 | 1 | 3
MDR | P. aeruginosa | 1 | 9 | 4

Our primary objective was to assess the availability and quality of published studies on the 15 selected pathogen-drug combinations that could support models of the AMR burden in the U.S. In so doing, we defined the key model parameters as mortality, length of stay (LOS), and healthcare costs for resistant and susceptible infections of interest and characterized the current state of the literature on those parameters. We also identified research gaps with respect to estimating those model parameters, and we compared pathogen-drug combinations on their capacity for AMR burden modeling. We reviewed 2,926 studies, 167 of which were included for analysis. Table ES - 2 shows, for each pathogen and drug, the number of available published estimates of resistant-strain mortality and resistant-strain LOS in the included literature. Cost data were far less common than mortality or LOS data, so costs were analyzed separately (see Section 5.1.9) and are excluded from the counts in Table ES - 2. The values in Table ES - 2 include both U.S. and non-U.S. studies. Comparing with Table ES - 1 shows there are more estimates than publications; this is because many publications provide multiple estimates for more than one infection site, such as bloodstream infections (BSIs), urinary tract infections (UTIs), pneumonia infections, or surgical site infections (SSIs).

Table ES - 2 Number of Resistant-Strain Mortality and LOS Estimates Available, by Pathogen-Drug Combination

Pathogen-Drug Combination | Number of Resistant-Strain Mortality Estimates | Number of Resistant-Strain LOS Estimates
Carbapenem-Resistant A. baumannii | 45 | 14
Carbapenem-Resistant K. pneumoniae | 33 | 8
Carbapenem-Resistant P. aeruginosa | 24 | 14
MDR P. aeruginosa | 20 | 11
MDR A. baumannii | 16 | 9
Carbapenem-Resistant E. aerogenes/E. cloacae | 12 | 12
3^rd^ Gen. Cephalosporin-Resistant E. coli | 13 | 8
3^rd^ Gen. Cephalosporin-Resistant K. pneumoniae | 12 | 7
Carbapenem-Resistant E. coli | 11 | 4
MDR E. coli | 10 | 5
MDR K. pneumoniae | 8 | 3
Fluoroquinolone-Resistant E. coli | 6 | 2
3^rd^ Gen. Cephalosporin-Resistant P. aeruginosa | 5 | 2
Fluoroquinolone-Resistant K. pneumoniae | 3 | 1
MDR E. aerogenes/E. cloacae | 1 | 0

Note: the total number of estimates may exceed the number of studies, as some studies contain multiple estimates.

All of the publications^4^ we included are relevant to AMR in general. However, the extent to which published estimates are suitable for modeling the current or future national AMR burden in the U.S. depends on several factors that relate to generalizability. We developed a scoring algorithm that accounts for the following four factors: the region where the study was conducted, the precision of the study’s estimate, the study design (cohort, case-control, or other), and the recency of data, as measured by the year when the study stopped enrolling participants. Each study was rated on each of these factors using a three-point scale, presented in Table ES - 3.

By aggregating these four components, we assigned each study an overall relevance score and categorized the studies as having low, medium, or high relevance. Throughout this report, we refer to the score as measuring a study’s overall relevance rather than overall quality because we acknowledge that we are attempting to use these studies for a task (national AMR burden modeling) that the studies were not originally designed for.

Table ES - 3 Scoring Methodology for Four Components

Feature of Study | 1 point | 2 points | 3 points
Final year when participants were enrolled | 1999-2006 | 2007-2013 | 2014-2020
Region where study was conducted | Other | Europe | U.S.
Precision of resistant-strain estimate ^[a]^ | Bottom tercile | Middle tercile | Top tercile
Study design | Other | Case-control study | Cohort study

[a] Precision refers to either the standard error of a resistant-strain mortality estimate, or the sample size associated with a resistant-strain LOS estimate.

Initial searching suggested that there would be too few U.S. publications to produce all required estimates, which was later confirmed through our literature review.^5^ We therefore included studies from other countries and did not restrict our search just to U.S. publications. We found that the region where a study was conducted often introduces the most variation into estimates of resistant-strain mortality and LOS. Whereas most of the components of the scoring algorithm attempt to capture data quality, region likely captures more fundamental differences. Because the underlying AMR-attributable mortality rates can vary substantially by region, studies conducted in different countries may be attempting to measure altogether different targets.

The presence of a large number of studies does not necessarily indicate that they are all highly relevant/suitable for the task of modeling national AMR burden in the U.S. Using a 1-3 scale (1 = low relevance, 2 = medium relevance, and 3 = high relevance), we found that only 20 percent of published studies achieve overall scores indicating high relevance to U.S. AMR burden modeling. Two features are primarily responsible for the small number of studies earning high scores: a vast majority of the studies were conducted in countries where AR mortality rates tended to differ from U.S. rates, and of the U.S. studies we identified, only three had enrollment periods extending past 2013. Of the included studies, those conducted in the U.S. tended to have slightly better precision (as measured by standard error or sample size) and made more frequent use of cohort designs but utilized slightly older data. Overall, resistant-strain mortality estimates were far more common than resistant-strain LOS estimates. Figure ES - 1 presents the distribution of studies based on relevance to AMR burden modeling. In this graph, studies with distinct estimates for different pathogen-drug combinations were counted multiple times.

In general, we found insufficient data in the literature to support infection-site-specific AMR burden modeling. This poses a major obstacle, as mortality and LOS vary widely across infection sites. For example, BSIs make up the vast majority of included studies yet are associated with substantially higher mortality rates than other infection types. Accordingly, building a burden model exclusively on these relatively abundant studies would lead to overestimation. However, even differentiating between just four infection sites (BSIs, UTIs, SSIs, and pneumonia) is not feasible based on the studies we included.

When comparing the 15 pathogen-drug combinations, we found that E. aerogenes/E. cloacae was the least-studied and A. baumannii and K. pneumoniae were the most-studied. Among the drug resistances, fluoroquinolones were the least studied and carbapenems were the most studied. However, simply because a pathogen-drug combination had a large number of studies did not imply that the studies all achieved high relevance scores, and this was especially true for A. baumannii.

Figure ES - 1 Distribution of Studies, by Relevance (Low, Medium, High)

Note: the designations (low, medium, and high) relate to a study’s relevance to modeling national AMR burden in the U.S. These designations are based on a composite score that considers (a) the region in which the study was performed, (b) the recency of data (as indicated by the final year of participant enrollment), (c) the precision of the estimates (as indicated by standard error or sample size), and (d) the type of design (e.g., cohort, case-control, or other).

This is a histogram showing the number of studies with low, medium, and high relevance. 104 studies have low relevance and scores less than 9. 40 studies have medium relevance and scores ranging from 9 to 15. 37 studies have high relevance with scores greater than 15.

One strategy for modeling overall AMR burden is to generate separate estimates or projections of the attributable mortality and LOS for specific infection sites, and then aggregate across all infection sites to acquire total attributable mortality and LOS, for a given pathogen-drug combination. The motivation for this type of granular approach is that mortality and LOS vary widely by infection site, for example, with BSIs tending to have higher mortality than UTIs. We found that none of the 15 pathogen-drug combinations had sufficient literature to support infection-site-specific mortality and LOS parameters. In the absence of infection-site-specific data, the alternative modeling approach is to use studies that were not focused on just a single infection. However, these studies similarly were too scarce, and they raise concerns of generalizability, as the distribution of infection sites in the study groups may not broadly represent the distribution in the full U.S. population. Accordingly, there is insufficient literature either for infection-site-specific modeling or non-infection-site-specific modeling.

For each pathogen-drug combination, we also assessed the extent to which comparable estimates agreed by evaluating the standard deviation (SD) of medium- or high-scoring estimates of the same pathogen, drug, and infection site. Then, for a given pathogen and drug, we averaged these metrics across the available infection sites. In general, we found that multi-drug resistance (MDR) tended to have less internal agreement, possibly due to conflicting definitions of MDR, and that fluoroquinolone resistance tended to have more agreement. For example, comparable estimates of fluoroquinolone-resistant K. pneumoniae had a mean SD of 0.5 percent, whereas comparable estimates of MDR A. baumannii had a mean SD of 21.6 percent.

In total, we evaluated each pathogen-drug combination on five components, which spanned the number of available studies, the relevance of the best available studies, the availability of data that could potentially represent all infection sites, and the extent of agreement within comparable estimates. Each criterion was converted into a three-point scale, as shown in Table ES - 4.

Table ES - 4 Components for Final Score of Each Pathogen-Drug Combination

Component | 1 point | 2 points | 3 points
Number of studies with a resistant-strain mortality or LOS estimate | 1-10 | 11-20 | 21-30
Mean score of the top-scoring resistant-strain mortality studies | 3-8 | 9-15 | 16-27
Mean score of the top-scoring resistant-strain mortality studies, limiting to “any infection” studies ^[a]^ | 3-8 | 9-15 | 16-27
Mean score of the top-scoring resistant-strain LOS studies | 3-8 | 9-15 | 16-27
Mean score of the top-scoring resistant-strain LOS studies, limiting to “any infection” studies | 3-8 | 9-15 | 16-27
Mean SD between comparable medium- or high-scoring estimates | >15% | 10-15% | <10%

[a] We define an “any infection” study as one that was not limited to just a single infection site and encompassed at least three infection sites.

Figure ES - 2 presents a final line plot of the relative strength of literature for national burden modeling of the 15 pathogen-drug combinations. The percentages in this figure combine the five components of Table ES - 4.^6^ Overall, we found that carbapenem-resistant pathogens tended to have the highest capacity for AMR burden modeling (including P. aeruginosa, K. pneumoniae, and A. baumannii), as did third-generation cephalosporin-resistant pathogens. MDR E. aerogenes/E. cloacae and MDR K. pneumoniae had the lowest capacity for burden modeling.

Figure ES - 2 Line Plot of Overall Scores for Each Pathogen-Drug Combination

This is a line plot showing the overall score for each pathogen-drug combination. The x axis is the overall score, expressed as a percentage. Each pathogen-drug combination is represented as a single point on the line plot. The scores in this figure are shown in the final column of Table 15.

1 In this report, we use “estimate” to refer to calculations of the current burden and “projection” to refer to calculations of future burden. “Model” refers to the calculations, underlying assumptions, input data, and output predictions.

2 As of 2020, E. aerogenes is now classified as K. aerogenes. However, in this report, we use the previous term E. aerogenes for consistency with CDC’s Antibiotic Resistance Threats in the United States, 2019 and literature published prior to 2020.

3 When very little literature was available, we broadened our search scope (e.g., including all fluoroquinolone-resistant Enterobacteriaceae when searching for fluoroquinolone-resistant K. pneumoniae). These instances are described in Section 4.1.

4 In this report, we use “publication” and “study” interchangeably, as each publication constituted a different study. In the context of these publications, the “estimates” refer to a published value of mortality, LOS, or cost.

5 Of the 167 distinct publications we included, 29 were conducted in the U.S. When aggregating counts of studies across study-pathogen combinations, 37 of 181 studies were conducted in the U.S. The second tabulation method gives greater weight to larger studies that reported outcomes for multiple pathogen-drug combinations, counting them multiple times.

6 As discussed in Section 5.2.7, the final percentage is acquired by summing the five component scores and dividing by the possible points. This final percentage accounts for the number of available publications, the relevance score of the publications, and the availability of data that is not limited to a single infection site.