# 6 CONCLUSION

We found that a variety of factors complicate modeling of current as well as future AMR burden. Long-term trends, particularly the efficacy of strategies for combatting AMR, can have potentially large impacts on drug resistance but are difficult to predict. Foundational modeling parameters such as LOS are not consistently defined in literature. Attributable values (of mortality and LOS) must be calculated relative to a counterfactual group, but there is disagreement on whether the counterfactual should be the susceptible strain or the no infection case. Secondary burden can be substantial but it is difficult to fully quantify. Hence, it is not as well-understood.

In general, the parameters that would be used to model AMR burden vary widely across infection site and healthcare setting, for example, with BSI infections having higher mortality rates than UTI infections. Healthcare-associated infections are generally associated with higher attributable mortality and higher attributable LOS than community-acquired resistant infections. However, adjusting for confounders such as age and comorbidities can affect the results, as hospital patients tend to be older with more risk factors than patients in community settings. While building an AMR model to account for these differences in outcomes across infection site and healthcare setting would improve the model’s accuracy, it also rapidly increases the number of parameters that must be estimated. This poses a challenge, as we found there are often insufficient data to estimate or project all of the required parameters. For example, while BSIs are well-studied, other common infection sites (particularly UTIs, SSIs, and pneumonia) are not as frequently studied. None of the 15 pathogen-drug combinations contained enough data to estimate or project AMR burden by these four distinct infection sites.

We inspected four study components that can impact a study’s relevance to AMR burden modeling: region, year when enrollment was closed (i.e., the age of the underlying data), precision of estimates, and study design. Region generally appeared to have the largest impact on a study’s reported estimates than the other three factors, and this is likely due to regional differences in AMR rates; studies conducted in a region with different healthcare practices may be estimating a fundamentally different quantity from U.S. AMR rates. When evaluating trends over time, literature relating to AMR burden parameters has been consistent since 2007. U.S. studies tended to have good precision and used a cohort design more frequently than any other study design. In general, data on mortality was far more abundant than data on LOS. Furthermore, LOS data were reported inconsistently (sometimes as a mean and in other instances as a median). Often, range information was not reported at all for LOS, making it difficult to estimate adequately the uncertainty associated with LOS—and consequently, any models based on that parameter.

When comparing the relative strength of literature across different pathogen-drug combinations, several patterns appeared. E. aerogenes/E. cloacae tends to receive the least research attention across the drug types, while A. baumannii and K. pneumoniae were found to have the most publications. Among the drug resistances, carbapenem is studied most, and fluoroquinolone is studied least. However, further analysis showed that the number of studies does not necessarily imply that they are highly relevant to modeling the AMR burden in the U.S.

Using the extracted study information, we computed an overall total score for each pathogen-drug combination. We found that third-generation cephalosporin-resistant E. coli, third-generation cephalosporin-resistant K. pneumoniae, and carbapenem-resistant P. aeruginosa had the highest scores (suggesting better capacity for AMR burden modeling). MDR K. pneumoniae and MDR E. aerogenes/E. cloacae had the least literature to support models of AMR burden in the U.S.

We found that there is wide variation in AMR rates across infection sites, pathogens, and AM drug resistance. Existing studies generally do not provide the necessary data for modeling specific infection sites or for modeling all pathogen-drug combinations. Overall, we found that literature is likely an insufficient data source for modeling the full economic burden of AMR in the U.S., as estimates from literature are rarely generated with this purpose in mind, leading to limitations in applicability and generalizability. However, other data sources may exist for estimating parameters (e.g., electronic health records and, potentially, CMS claims data).