# 5 RESULTS

The literature review resulted in a total of 2,926 reviewed studies and 167 included studies. The number of studies included for a single pathogen-drug combination ranged from 1-30 and is discussed in detail below. The number of included studies represented between 3-15 percent of the total number of studies reviewed for each combination. The total number of studies reviewed, studies included, and the ratio of included over reviewed are presented in Table 6.

In most cases, 50 to 80 percent of the total studies identified for a pathogen-drug combination were excluded in the title and abstract review. Of the remaining studies, approximately 50 percent were typically excluded during the full-text review. Table 6 presents the number of studies that were reviewed and included, for each of the selected pathogen-drug combinations.

Table 6 Results on Number of Studies Reviewed and Included for All Pathogen-Drug Combinations

Pathogen | Antimicrobial Drug Class | CDC Threats Report Designation | WHO Pathogen Priority List | Number of PubMed Results | Number of WoS Results | Additional Studies ^[a]^ | Number of Included Studies | Percentage of Studies Included
A. baumannii | Carbapenems | urgent | Critical | 206 | 78 | 5 | 28 | 10%
A. baumannii | Resistant to all three classes | urgent | | 297 | 119 | | 16 | 4%
E. coli | Carbapenems | urgent | critical | 106 | 62 | 1 | 8 | 5%
E. coli | Fluoroquinolones | | | 137 | 30 | | 6 | 4%
E. coli | Third-generation Cephalosporins | serious | critical | 147 | 34 | | 12 | 7%
E. coli | Resistant to all three classes | urgent | | 181 | 196 | | 12 | 3%
K. pneumoniae | Carbapenems | urgent | critical | 291 | NA ^[b]^ | | 30 | 10%
K. pneumoniae | Fluoroquinolones | | | 43 | 15 | 3 | 3 | 5%
K.pneumoniae | Third-generation Cephalosporins | serious | critical | 90 | 16 | 1 | 12 | 11%
K.pneumoniae | Resistant to all three classes | urgent | | 178 | 130 | | 9 | 3%
P. aeruginosa | Carbapenems | serious | critical | 148 | 40 | 3 | 21 | 11%
P. aeruginosa | Ceftazidime | serious | | 63 | 53 | | 5 | 4%
P. aeruginosa | Resistant to all three classes | serious | | 288 | 195 | | 14 | 3%
E. aerogenes/E. cloacae | Carbapenems | urgent | critical | 21 | 6 | | 4 | 15%
E. aerogenes/E. cloacae | Resistant to all three classes | urgent | | 19 | 12 | | 1 | 3%

[a] Additional studies may include studies reviewed for a different pathogen-drug combination and deemed relevant, studies from a supplementary Google search, studies mentioned in additional systematic reviews identified through our search, or studies identified using the reference list of another study.

[b] NA = Not applicable. We did not perform a WoS search for carbapenem-resistant K. pneumoniae (CRKP) because it served as a test case for refining the search criteria. For CRKP, exhaustive searches using a variety of terms were performed on several platforms, resulting in 30 included studies. Then, CRKP searches were performed in PubMed, and the search terms were refined until all 30 CRKP studies were retrieved.

## 5.1 FINDINGS ON AMR LITERATURE, ACROSS ALL PATHOGEN-DRUG COMBINATIONS

In this section, we present study-level statistics in order to characterize the current state of AMR literature in general, across all pathogen-drug combinations. Section 5.1.1 introduces a methodology for scoring studies to assess their relevance and generalizability for modeling the national burden of AMR in the U.S. This score is based on four components, which are discussed in detail in Sections 5.1.2 through 5.1.5—final enrollment year, region, study design, and precision. We analyzed the availability of mortality and LOS data (Section 5.1.6), including the availability of studies specific to a particular infection site (Section 5.1.7). While mortality estimates tend to be more abundant, they are also more consistently reported; in Section 5.1.8, we discuss some of the issues associated with inconsistent reporting of LOS. Finally, in Section 5.1.9, we assess the available data on healthcare costs, which was far sparser and thus analyzed separately from the mortality and LOS publications.

The analysis of 5.1 does not compare the availability or quality of literature across pathogen-drug combinations. Rather, it provides an overall evaluation of the included literature. In the next section (5.2), we make comparisons between specific pathogen-drug combinations and discuss specific pathogen-drug combinations with greater capacity for burden modeling.

### 5.1.1 Overall Study Scores

Figure 2 displays a scale of possible study scores using the algorithm of Equation 1.^22^ The scale ranges from 3 (a 1 in all components) to 27 (a 3 in all components), with a central value of 12 (equivalent to a 2 in all components). The three shaded regions represent low scores (<9), middle scores (9-15), and high scores (>15).

Figure 2 Scale of Possible Study Scores

This is an illustration of the scale of possible study scores. Each line on the scale represents a score that can be attained from Equation 1. A score of 3 corresponds to a study that earns a 1 on all components and is the lowest value on the scale. A score of 12 corresponds to a study that earns a 2 on all components and is the middle value on the scale. A score of 27 corresponds to a study that earns a 3 on all components and is the highest value on the scale. The scale is broken into three regions: 3 through 8 corresponding to low relevance, 9 through 15 corresponding to medium relevance, and 16 through 27 corresponding to high relevance.

Far more studies fall into the low score range (colored red in Figure 2) than the middle or high score ranges. Below, Figure 3 displays the distribution of studies in these three score ranges. The lowest scoring group is more than twice the size of either of the other two groups.

Figure 3 Distribution of Low, Middle, and High Scores

This is a histogram showing the number of studies with low, medium, and high relevance. 104 studies have low relevance and scores less than 9. 40 studies have medium relevance and scores ranging from 9 to 15. 37 studies have high relevance with scores greater than 15.

The discrepancy in study scores is largely attributable to imbalances in region. Figure 4 presents distributions for each component score. One hundred four of the 181 studies, or 57 percent, were conducted in a region other than the U.S. or Europe. Figure 4 also shows that a second area of relative imbalance is the final enrollment year, with many studies closing their enrollment period between 2007 and 2013.

Figure 4 Distribution of the Four Component Scores, Among All Studies

This is a series of histograms showing the distribution of studies for each of the four component scores. For the design score, 64 studies used a cohort design and earned a 3, 48 studies used a case-control design and earned a 2, and 69 studies used a different design and earned a 1. For the final enrollment year score, 45 studies closed enrollment between 2014 and 2021 and earned a 3, 104 studies closed enrollment between 2007 and 2013 and earned a 2, and 32 studies closed enrollment between 1999 and 2006 and earned a 1. For the precision score, 43 studies had the greatest precision and earned a 3, 72 studies had medium precision and earned a 2, and 66 studies had the least precision and earned a 1. For the region score, 37 studies were conducted in the U.S. and earned a 3, 43 studies were conducted in Europe and earned a 2, and 101 studies were conducted in another region and earned a 1.

### 5.1.2 Enrollment Year

Figure 4 shows that there is not equal distribution of studies with regard to the final year participants were enrolled.^23^ Only 45 studies, or 25 percent, had enrollment periods that extended beyond 2013. The remaining 75 percent were based on enrollment periods that were at least eight years in the past when the literature review was conducted in 2021. Across all studies, the final year of enrollment was 2012 on average, and the latest enrollment year of any study was 2019. Figure 5 shows that, among the included studies, the annual number of publications per year varies widely but does not display a clear trend.

Figure 5 Annual Number of Studies Published and Annual Number of Studies Closing Enrollment

This is a time series graph showing the number of studies, by region. Each region has two lines: one showing the number of studies closing enrollment each year, and the other showing the number of studies published each year. For all three regions–the U.S., Europe, and Other–both trends are generally flat.

Figure 5 also shows a lack of trend in final enrollment year. Notably, U.S. studies have older enrollment closure dates; only three U.S. studies enrolled participants after 2013, suggesting that the included U.S. studies represent older data.

### 5.1.3 Region of Study

The region where a study was conducted was found to introduce substantial variation across estimates, and this effect is not surprising given differences in healthcare systems. Table 7 presents the average deviation of non-U.S. regions’ resistant-strain mortality estimate from U.S. studies’ corresponding estimate. The values of Table 7 are averaged across the unique combinations of pathogen, drug, and infection site (BSI, UTI, etc.) for which comparison with U.S. estimate(s) was possible. For example, 12 different pathogen-drug-infection combinations existed with at least one European study and at least one U.S. study. The difference between these two regions’ mean estimates—across all 12 combinations—was 6.2 percent.

Table 7 Deviation from U.S. Estimates of Resistant-Strain Mortality

Region/Country | Mean Difference from U.S. Estimate of Resistant-Strain Mortality ^[a]^ | Number of Pathogen-Drug-Infections where Comparison with U.S. Estimate was Possible
Europe | 6.2% | 12
Australia | -8.9% ^[b]^ | 1
Mexico | 15.2% | 2
Asia ^[c]^ | 17.0% | 15
Middle East | 18.4% | 5
South America | 26.6% | 11
Africa | 30.3% | 3

[a] Each region/country’s deviation from the mean U.S. estimate was computed for every unique pathogen-drug-infection combination. Values presented here represent averages across all pathogen-drug-infection combinations for which comparison with a mean U.S. estimate was possible.

[b] A negative value indicates that Australia had lower resistant-strain mortality estimates than the U.S.

[c] None of the included studies were conducted in Japan.

Notably, studies from Europe are the most similar to U.S. studies on average, and this relative similarity (compared to other regions) between U.S. mortality and European mortality rates is part of the justification for assigning a region score of 2 for European study estimates.

### 5.1.4 Study Design

We categorized the study design into three categories: cohort, case-control, and other. Figure 6 shows the proportion of studies with each type of design, by region.

Figure 6 Distribution of Study Design, by Region

This is a series of graphs showing the distribution of included studies’ epidemiological designs, for each of the three regions: U.S., Europe, and Other. Among U.S. studies, 59 percent used a cohort design, 30 percent used a case-control design, and 11 percent used a different design. Among European studies, 47 percent used a cohort design, 21 percent used a case-control design, and 33 percent used a different design. Among studies conducted in other regions, 22 percent used a cohort design, 27 percent used a case-control design, and 51 percent used a different design.

The U.S. has the highest proportion of cohort studies, at nearly 60 percent. Across all regions, 35 percent of studies used a cohort design, 27 percent used a case-control design, and 38 percent used another design.

### 5.1.5 Precision of Estimates

Among all resistant-strain mortality estimates from all studies, the SE ranged from 0.4 percent to 25.0 percent. The mean SE is 6.3%, which would correspond to a margin of error of ±12.4 percentage points, assuming a 95 percent confidence interval and a normal sampling distribution. LOS sample size ranged from 5 to 1,617 participants and was heavily right skewed, with a mean of 126.6 and a median of 66.0. Table 8 presents the terciles—computed across all pathogen-drug combinations—that served as cut points for the precision scores.

Table 8 Precision Terciles

Tercile | Standard Error in Resistant-Strain Mortality | Sample Size of Resistant-Strain LOS
Bottom Tercile (Precision Score = 1) | <4.6% | <46
Middle Tercile (Precision Score = 2) | 4.6-7.0% | 46-91
Top Tercile (Precision Score = 3) | >7.0% | >91

U.S. studies generally had better precision than other regions. Across all U.S. studies, the average resistant-strain mortality SE is 3.9 percent (compared to 6.4 percent in European studies and 7.4 percent in other regions), and the median resistant-strain LOS sample size is 91.5 (compared to 46.5 in European studies and 64.0 in other regions). These differences are evident in Figure 7, which display the distribution of precisions by country and parameter (mortality vs. LOS). Good precision corresponds to high sample size and low SE.

Figure 7 Comparing Precision of Studies across Regions, by Parameter Type

[a] For visualization, two studies with sample sizes equal to 809 and 716 are displayed here as having a sample size of only 300.

[b] The left set of plots show LOS sample size, with larger size corresponding to better precision. The right set of plots shown mortality SE, with smaller values corresponding to better precision.

This is a series of histograms that show the precision of the included studies, by region and parameter type. The histograms are arranged in a grid with three rows corresponding to the three regions– U.S., Europe, and Other–and two columns corresponding to the two parameters–resistant-strain mortality and resistant-strain LOS. The histograms on the left side show the distribution of sample sizes associated with the resistant-strain LOS estimates. The histograms on the right side show the distribution of standard errors associated with the resistant-strain mortality estimates. There are not large differences between regions. However, U.S. studies tend to have resistant-strain mortality estimates with lower standard error.

### 5.1.6 Mortality vs. Length of Stay

The preceding sections introduced the overall scoring metric and analyzed the four components of the score. In Section 5.1.6 and 5.1.7, we compare the availability of mortality vs. LOS estimates, and we consider whether the available studies are well-distributed across the various infection sites that contribute to the overall burden.

We found that mortality estimates are available in far greater numbers than LOS estimates. Our literature review identified and included 169 unique studies with resistant-strain mortality estimates and 88 unique studies with resistant-strain LOS estimates.^24^ Some studies contain multiple mortality estimates for different infection sites, leading to 219 different resistant-strain mortality estimates and 100 different resistant-strain LOS estimates (across all pathogen-drug-infection combinations).

On average, for each pathogen-drug combination, we found 14.6 unique studies with resistant-strain mortality estimate(s), compared to only 6.7 unique studies with resistant-strain LOS estimate(s). However, the computed score of study estimates does not vary substantially across LOS and mortality. Resistant-strain mortality estimates produce a study score of 10.7 on average, and LOS estimates produce a study score of 9.9 on average. These scores fall in the middle range of the scale in Figure 2, indicating moderate relevance to modeling AMR burden in the U.S. Among LOS studies, 65.9 percent have a cohort or case-control design, while 60.0 percent of mortality studies have such designs. Across the three regions, no large imbalances exist in the rate at which a study reports mortality vs. LOS data; however, U.S. and European studies report LOS information at a slightly lower rate than the region “Other.”

### 5.1.7 Infection Site

A major consideration when modeling AMR burden is the site of infection (BSI, UTI, SSI, pneumonia, etc.). Distinct infection sites can have very different mortality rates and lengths of stay, as the included studies show. To illustrate this difference, Table 9 presents mean mortality rate and mean LOS across carbapenem-resistant K. pneumoniae studies, by infection site. The mean mortalities range from 15.6 percent (among other infection sites) to 54.5 percent (among BSIs). The mean LOS values range from 14.0 days (among BSIs) to 99.5 days (among multiple types).

Table 9 Mean Parameter Estimates for Carbapenem-Resistant K. pneumoniae, by Infection Sites

Infection Site ^[a]^ | Resistant-Strain Mortality | | Resistant-Strain LOS in Days
Infection Site ^[a]^ | Mean Estimate | Number of Estimates | Mean Estimate ^[b]^ | Number of Estimates
BSI | 54.5 | 9 | 14.0 | 1
Not determined | 38.3 | 7 | 46.0 | 1
Any infection | 38.3 | 7 | 51.6 | 3
Pneumonia | 28.5 | 3 | 19.0 | 1
UTI | 23.4 | 4 | 10.0 | 1
Multiple types | 21.9 | 2 | 99.5 | 1
Other | 15.6 | 1 | NA | 0

[a] The designation “multiple types” refers to studies where the sample contained two infection sites. “Any infection” refers to studies that did not screen participants based on infection site or had three or more infection sites. “Other” refers to a study with a single infection site not included in this list (e.g., intra-abdominal).

[b] While mean values are reported, different studies used different metrics to quantify LOS (e.g., means vs. medians). The usefulness of such means across different estimation metrics may be limited.

[c] NA = not applicable

Applying the attributable mortality rate from a BSI study to the full U.S. population (which is inflicted with a variety of infection sites) would likely lead to overestimation. Effective AMR burden modeling must account for these differences across infection sites, particularly given that many studies do not contain representative samples of the infection sites that exist in the U.S. in general.

The need for infection-site-specific data complicates matters by greatly expanding the number of parameters that must be estimated for effective modeling. Estimating or projecting burden based on attributable mortality and attributable LOS for 15 pathogen-drug combinations and four infection sites (BSI, UTI, SSI, and pneumonia) necessitates 15 combinations × 2 parameters × 4 infection sites = 120 estimates.

Table 10 presents the total number of estimates that were available for each infection site based on our search, as well as the number of high-scoring estimates (i.e., those with an associated total study score of >15). The total number of high-scoring estimates included from the literature review is less than what is required.

Table 10 Number of Studies by Infection Site and Parameter

Infection Site | Resistant-Strain Mortality | | Resistant-Strain LOS
Infection Site | Total Number of Studies | Number with High Score | Total Number of Studies | Number with High Score
Any ^[a]^ | 77 | 12 | 42 | 8
BSI | 64 | 17 | 31 | 7
Pneumonia | 25 | 6 | 12 | 1
UTI | 19 | 9 | 6 | 3
Other | 15 | 4 | 4 | 0
Not determined | 15 | 2 | 3 | 0
Multiple | 3 | 2 | 2 | 0
SSI | 1 | 0 | -- | 0
Total ^[b]^ | 219 | 52 | 100 | 19

[a] An “any infection”-study is defined as a study with whose infections encompass three or more infection sites.

[b] Studies with multiple estimates for a single pathogen-drug are counted multiple times (once for each estimate of a distinct pathogen-drug-infection site combination).

Notably, studies on “any infection site”—defined to be a study that did not limit its sample to specific infection sites or had samples composed of three or more different infection sites—make up the majority of publications. Among individual infection sites, estimates for BSI are more than twice as common as for any other infection site. Of the 219 mortality estimates and 100 LOS estimates, only one was for a population whose infection originated from a SSI. As discussed in detail in Section 5.2.3, the lack of research on certain infection sites—particularly with LOS estimates—is a major obstacle to building an AMR burden model that accounts for differences in mortality and LOS across infection sites.

### 5.1.8 Inconsistent Length of Stay Reporting

Overall, studies did not consistently define or report LOS. Some examples of LOS definitions include number of ICU days, total hospital stay, time in hospital after disease onset, and time after a culture was taken. Furthermore, some studies reported mean LOS, while others reported median LOS. Information about the spread or distribution of LOS data was often omitted altogether, but when it was reported, it varied between standard deviation, quartiles, and range. This inconsistency poses a challenge in estimating LOS parameters, but some techniques may be available to extract comparable metrics from studies that report different statistics.

A comprehensive study by Marazzi et al. (1998) evaluated distributional fits for LOS data and analyzed the extent to which studies report LOS range information. They proposed lognormal, Weibull, and Gamma distributions as the primary parametric candidates and found that lognormal models generally had good fits. Based on this finding, we attempted to fit lognormal distributions to studies that reported quartiles and generally were successful. This allowed us to extract mean LOS and standard deviation in LOS from the reported quartiles, thereby acquiring a consistent metric across all studies.

While it was often possible to achieve good fits to the reported quantiles, this approach relies heavily on the assumption of LOS data being lognormally distributed. We used Mark et al. (2021) as a case study to analyze this assumption, as Mark et al. not only reported LOS quantiles but also median and standard deviation (Mark, et al., 2021). Figure 8 and Figure 9 show the quartiles and the fitted lognormal cumulative distribution function both for the resistant LOS and susceptible LOS distributions of Mark et al. (2021), respectively.

Figure 8 Reported Resistant LOS Quartiles and Fitted Lognormal CDF for Mark et al.

This is a graph showing the lognormal distribution that was fit to the resistant-strain LOS quartiles published in Mark et al. (2021). The y axis is the cumulative distribution function, and the x axis is the quantile. The graph contains a curve corresponding to the fitted cumulative distribution function, and three points corresponding to the published quartiles. The curve passes very closely to the three points, which shows that the fitted distribution is a good fit of the published quartiles.

Figure 9 Reported Susceptible LOS Quartiles and Fitted Lognormal CDF for Mark et al.

This is a graph showing the lognormal distribution that was fit to the susceptible-strain LOS quartiles published in Mark et al. (2021). The y axis is the cumulative distribution function, and the x axis is the quantile. The graph contains a curve corresponding to the fitted cumulative distribution function, and three points corresponding to the published quartiles. The curve passes through the three points, which shows that the fitted distribution is a good fit of the published quartiles.

From the fitted lognormal distributions, we computed the mean and standard deviation and compared them to the reported values in Mark et al. (2021). This comparison is shown in Table 11.

Table 11 Comparing Reported and Fitted Distribution Parameters for LOS in Mark et al. (2021)

Distributional Parameter | Value Reported in Mark et al. (2021) | Value Calculated from Fitted Lognormal Distribution
Mean LOS among resistant strain | 115.4 | 104.5
Mean LOS among susceptible strain | 87.1 | 77.1
St. dev. in LOS among resistant strain | 117.8 | 59.5
St. dev. LOS among susceptible strain | 98.6 | 42.4

The calculated means are very close to the values reported in Mark et al. (2021) and would likely be suitable for AMR modeling purposes. The computed standard deviations are approximately half the value reported in Mark et al. (2021) and would require an adjustment to correct for the lack of fit. In general, this approach of fitting a lognormal distribution to reported quartiles and calculating the associated mean may provide a way to extract a consistent metric from LOS studies.

### 5.1.9 Excess Healthcare Costs

The preceding sections analyzed studies on mortality and LOS but excluded studies on healthcare costs. In the literature we included, information on the costs associated with AMR was far less common than mortality or LOS data. For this reason, we present a separate analysis of healthcare costs in this section, for all pathogen-drug combinations.

Healthcare costs vary significantly by site of infection. While an UTI may require a course of antibiotics that can be administered in outpatient settings, some UTI cases may need hospitalization (MacVane, et al., 2014). An SSI may require debridement or intravenous antibiotics (Maruo & Berven, 2014) administered in the hospital. Zimlichman et al. (2013) found that UTIs had the lowest healthcare costs ($1,108 in 2020 $), followed by SSIs ($25,698 in 2020 $). BSIs cost ($45,814 in 2020 $) slightly more than pneumonia cases ($40,144 in 2020 $), much more than the other infection sites. The LOS associated with these infections correlate directly with the estimated healthcare costs; with longer hospital stays resulting in higher healthcare costs, except for BSIs which tend to have shorter hospital stays but higher healthcare costs compared to pneumonia, SSI, and UTI.

The previously described literature review process did not return studies with cost estimates. Through a separate search process, we identified a total of nine studies^25^ (U.S. only) that reported excess healthcare costs for different pathogens and infection sites (see Appendix D).^26^ Six out of nine studies used the same counterfactual as this study (i.e., susceptible infection). Some of the six studies covered multiple infection sites and/or resistant pathogens yielding a total of 11 excess healthcare cost (i.e., difference between resistant-strain healthcare costs and susceptible-strain healthcare costs in 2020 $) estimates across infection sites (Table 12). Of the six studies, two reported excess healthcare costs for UTIs; MacVane et al. (2014) for ESBL Escherichia coli and Klebsiella spp. and Neidell et al. (2012) for an unspecified resistant pathogen. There was only one study each with reported excess healthcare costs for BSIs and pneumonia and four studies total for an unspecified resistant pathogen. There were no studies that provided estimates specific to SSIs. Table 12 presents the pooled excess healthcare cost estimates across our study sample.

Table 12 Excess Healthcare Costs due to CRKP (in 2020 $), by Infection Site

Infection Site | N | Excess Healthcare Costs (in 2020 $) ^[a]^
Infection Site | N | Mean | Lower Bound ^[c]^ | Upper Bound
BSI | 1 | $38,191 | $8,456 | $67,927
Pneumonia | 1 | $20,153 | $7,751 | $32,695
UTI | 3 | $5,035 | -$28,608 | $40,587
ABSSSI ^[b]^ | 1 | $627 | -$1,011 | $2,277
Unspecified | 5 | $23,492 | -$8,315 | $74,409

[a] We used the seasonally adjusted medical care consumer price index (Consumer Price Index for All Urban Consumers: Medical Care in U.S. City Average, Index 1982-1984=100, Annual, Seasonally Adjusted) to scale the figures reported in each study to 2020 dollars. Use of a producer-based index (PPI) rather than a consumer-based index (CPI) would have resulted in slightly lower $ 2020 values.

[b] ABSSSI = Acute bacterial skin and skin structure infection

[c] According to the source study by Neidell et al. (2012), certain types of resistant infections actually had lower healthcare costs than resistant ones resulting in negative “excess” costs.

### 5.1.10 Summary of Study-Level Comparisons

In Section 5.1, we showed that a large majority of included studies have lower scores (<9), indicating less relevance to modeling the AMR burden in the U.S. Only 20.4 percent of studies (n=37) received a high score (>15), which would indicate greater relevance for supporting models of U.S. AMR burden. Much of this imbalance in relevance is due to 56.0 percent of included studies having been conducted in non-U.S. regions where the true mortality rate is more likely to differ from the target rates in the U.S. Even when the study is designed and conducted rigorously, non-U.S. estimates may have limited applicability to U.S. AMR burden modeling, owing to important differences in healthcare systems. The extent to which AMR poses a substantial burden can vary across regions, making it inappropriate to average mortality estimates from countries with substantially different AMR mortality rates. We found this to be true when comparing resistant-strain mortality estimates across regions; non-European regions having resistant-strain mortality rates that differ from U.S. estimates by 9 percent to 30 percent on average, whereas European estimates differ by six percent on average. These discrepancies likely reflect underlying differences in the true mortality rates. Within the three region categories (U.S., Europe, Other), the proportion of cohort studies is highest in the U.S., though U.S. studies tend to use older data than studies conducted in Europe or another region. U.S. studies also tend to have higher precision, primarily driven by larger samples sizes. There are approximately twice as many mortality estimates as LOS estimates, which is particularly problematic when attempting to model the AMR burden for less-studied pathogen-drug combinations.

An important element to control for is the site of infection. For example, for carbapenem-resistant K. pneumoniae, the mean resistant-strain BSI mortality rate is more than twice the mean resistant-strain UTI mortality rate (54.5 percent and 23.4 percent, respectively). However, infection sites are not studied evenly. We found more resistant-strain BSI estimates (n=64) than all other single-infection sites combined (n=60 for pneumonia, UTI, SSI, and other types).

In summary, more than half of studies have low scores, suggesting limited application to AMR burden modeling. Furthermore, there are substantial gaps in literature. Many infection sites have very little data, and LOS data are much sparser than mortality data. Additionally, the region being studied can introduce large variation in the magnitude of estimates.

## 5.2 COMPARISONS BETWEEN PATHOGEN-DRUG COMBINATIONS

Section 5.1 presented study-level statistics and comparisons. This section discusses differences between the 15 pathogen-drug combinations to highlight gaps in the literature for specific pathogens and drugs that may be of interest for modeling. Section 5.2.1 evaluates the number of studies published on each pathogen-drug combination and shows that carbapenem resistance is generally studied at a more than the other drug resistance phenotypes. In Section 5.2.2, we show that simply because a pathogen-drug combination has a high number of publications does not imply that the publications are all highly relevant to national burden modeling. Section 5.2.3 considers infection sites and shows that, while infection-site-specific data are more abundant for carbapenem resistance, this is primarily due to a single study. No pathogen-drug combination has sufficient data for site-specific modeling. In Sections 5.2.4 and 5.2.5, we compare the mean relevance score for each pathogen-drug combination, when considering mortality data and LOS data.

The score metric accounts for some factors that introduce variability, but there are other potential issues, such as whether a study is representative of the broader U.S. population, and the extent to which confounding variables are controlled. Section 5.2.6 captures these potential issues by analyzing the overall variability between comparable estimates. Comparable MDR mortality rates tend to have less internal agreement, and fluoroquinolone-resistant mortality rates tend to have more internal agreement. In Section 5.2.7, we aggregate all of the preceding components into a single percentage score and rank the 15 pathogen-drug combinations by their relative capacity for national burden modeling based on the available literature. Finally, because these analyses focus on resistant-strain mortality and LOS, we address susceptible-strain mortality and LOS in Section 5.2.8.

### 5.2.1 Number of Studies per Pathogen-Drug Combination

The number of AMR studies varies across the five pathogens and four AM drugs we investigated. Counts of publications can provide useful indicators of research interest and available funding. Figure 10 displays a heat map of the number of unique identified studies across the pathogens and drugs. Gray cells appear for combinations that were excluded from the literature review.

Figure 10 Heat Map of Number of Studies, by Pathogen-Drug Combination

Note: Gray cells correspond to pathogen-drug combinations that were not investigated.

This is a heat map with the five pathogens on the x axis and the four drug resistance phenotypes on the y axis. Each cell corresponds to a different pathogen-drug combination. The cell’s color indicates the number of included studies. MDR A. baumannii has 16 studies, MDR E. coli has 12 studies, MDR E. aerogenes/E. cloacae has 1 study, MDR K. pneumoniae has 9 studies, MDR P. aeruginosa has 14 studies, fluoroquinolone-resistant E. coli has 6 studies, fluoroquinolone-resistant K. pneumoniae has 3 studies, third-generation cephalosporin-resistant E. coli has 12 studies, third-generation cephalosporin-resistant K. pneumoniae has 12 studies, third-generation cephalosporin-resistant P. aeruginosa has 5 studies, carbapenem-resistant A. baumannii has 28 studies, carbapenem-resistant E. coli has 8 studies, carbapenem-resistant E. aerogenes/E. cloacae has 4 studies, carbapenem-resistant K. pneumoniae has 30 studies, and carbapenem-resistant P. aeruginosa has 21 studies.

Figure 10 suggests that fluoroquinolone resistance is studied much less frequently than other forms of resistance, with only 4.5 studies per pathogen on average. This may be a consequence of declining fluoroquinolone prescriptions from 2011 to 2018 relative to other classes (CDC, n.d.). In contrast, carbapenem resistance is the most-researched form of resistance and has the highest study count for nearly every type of pathogen. Among the various pathogens, E. aerogenes/E. cloacae have been studied least, with only 2.5 studies on average across MDR and carbapenem resistance—substantially below the average of 17.3 in those drug categories among the other pathogens. The most-studied pathogens are K. pneumoniae, with 54 total studies across the four drugs, and A. baumannii, with 44 total studies across the two most-researched drugs (carbapenem and multi-drug resistance).

### 5.2.2 Strength of Literature across Pathogens and Drugs

The number of studies is an important metric for a pathogen-drug combination, but it does not convey how relevant the studies are to AMR burden modeling in the U.S. To understand relevance, we analyzed the computed study scores presented in Section 5.1.1. Figure 11, below, presents the distribution of study scores for each pathogen-drug combination. The total area of each graph conveys the number of studies, and their placement along the x-axis represents their study scores.

Figure 11 Distribution of Study Scores by Pathogen and Drug

[a] The study scores convey the study’s relevance to AMR burden modeling by aggregating component scores based on the study’s design, precision, final enrollment year, and region.

[b] Gray cells correspond to pathogen-drug combinations that were not investigated.

This is a series of histograms showing the distribution of study scores for each pathogen-drug combination. The histograms are arranged in a grid with five columns for the five pathogens and four rows for the four drug resistance phenotypes.

As the distributions show, having a higher number of studies does not necessarily imply that the studies are highly relevant to the task of modeling U.S. AMR burden. MDR A. baumannii has 16 studies, but only three have scores higher than 12. Many of the pathogen-drug combinations with the most studies have at least one high-scoring study (with a score >15), but, as discussed previously, no combination has enough studies for infection-site-specific AMR burden modeling.

Importantly, when modeling AMR burden, a large number of studies per parameter is not always required. For example, a single study with a highly reliable and generalizable estimate for attributable mortality among fluoroquinolone-resistant E. coli BSIs obviates the need for additional literature on the same parameter. While having multiple study estimates for the same parameter does confer some benefits (e.g., pooling estimates using meta-analysis techniques), modeling can proceed with even just a single reliable and relevant estimate.

Given that a small number of high-scoring studies can be suitable for developing AMR burden models, we performed additional analysis on a subset of the strongest studies from each pathogen-drug combination. These analyses are presented in Sections 5.2.4 and 5.2.5.

### 5.2.3 Infection Site

As discussed in Section 5.1.7, an effective AMR burden model will account for important differences in attributable mortality and attributable LOS by using separate estimates for each infection site. We analyzed the 15 pathogen-drug combinations for their suitability to support a model with four infection sites: BSI, UTI, pneumonia, and SSI. We found that none of the pathogen-drug combinations met the requirement of possessing at least one estimate for each modeling parameter. This was true even when we included lower-relevance studies as candidates for estimating parameters. When we examined only studies with high scores (>15), the available studies dropped substantially.

Table 13 presents the infection sites for which estimation is possible, by pathogen-drug combination. The first two columns show the infection sites that can be estimated from literature (using at least one publication). The last two columns show the counts when restricting to high-scoring estimates (>15).

Table 13 List of Infection Sites with Literature to Support a Resistant-Strain Estimate

Pathogen-Drug Combination | Infection Sites with Any Available Estimate | | Infection Sites with a High-Scoring Estimate ^[a]^
Pathogen-Drug Combination | Mortality ^[b]^ | LOS | Mortality | LOS
Carbapenem, A. baumannii | BSI PNE SSI UTI | BSI PNE ^[c]^ | BSI PNE UTI | None
Carbapenem, E. coli | BSI PNE UTI | None | BSI PNE UTI | None
Carbapenem, Enterobacter | BSI PNE UTI | BSI PNE UTI | None | None
Carbapenem, K. pneumoniae | BSI PNE UTI | BSI PNE UTI | BSI PNE UTI | BSI PNE UTI
Carbapenem, P. aeruginosa | BSI PNE UTI | BSI PNE | BSI PNE UTI | None
Cephalosporin ^[d]^, E. coli | BSI UTI | BSI UTI | BSI UTI | BSI UTI
Cephalosporin, K. pneumoniae | BSI UTI | BSI UTI | UTI | BSI UTI
Cephalosporin, P. aeruginosa | BSI | None | None | None
Fluoroquinolone, E. coli | BSI UTI | BSI | BSI | BSI
Fluoroquinolone, K. pneumoniae | BSI | BSI | BSI | BSI
MDR, A. baumannii | BSI PNE | BSI PNE | None | None
MDR, E. coli | BSI PNE UTI | BSI | UTI | None
MDR, Enterobacter | None | None | None | None
MDR, K. pneumoniae | BSI | BSI | None | None
MDR, P. aeruginosa | BSI PNE UTI | BSI PNE UTI | BSI UTI | BSI

[a] A high-scoring estimate is one that produces an overall study score >15, indicating high relevance to the task of U.S. AMR burden modeling.

[b] Mortality and LOS refer to resistant-strain mortality and resistant-strain LOS, respectively.

[c] PNE indicates pneumonia.

[d] Cephalosporin refers to third-generation cephalosporin.

In Table 13, a pathogen-drug combination would be sufficiently supported by literature for AMR burden modeling if all four infection sites (BSI, PNE, SSI, UTI) appeared under both Mortality and LOS, indicating that at least one study was available for each required parameter. No study achieves this requirement for infection-specific modeling using the four selected infection sites. Some carbapenem-resistant pathogens have enough literature to support six of the eight required parameters, including A. baumannii, E. aerogenes/E. cloacae, and K. pneumoniae. Carbapenem-resistant K. pneumoniae has the most comprehensive literature coverage of specific infection sites. Notably, MDR E. aerogenes/E. cloacae does not have any infection-specific estimates, and third-generation cephalosporin-resistant P. aeruginosa only has one infection-specific estimate.

In general, literature was much sparser for attributable LOS than for attributable mortality, as Table 13 shows. When restricting to high-scoring studies, five of the 15 pathogen-drug combinations completely lacked infection-specific mortality data, and nine were lacking in infection-specific LOS estimates.

The analysis above shows that none of the pathogen-drug combinations have sufficient literature for infection-site-specific modeling. In some cases (such as carbapenem-resistant K. pneumoniae), higher-quality literature is available for most of the required parameters, and it may be possible to supplement the missing data with other assumptions, substitutions, or broadening of definitions. However, in general, this is not likely to be sufficient to fill in the gaps for the other pathogen-drug combinations.

### 5.2.4 Resistant-Strain Mortality Across Pathogen-Drug Combinations

To evaluate the relative strength of literature for supporting estimates of resistant-strain mortalities, we used the following procedure: each study was scored on the basis of its resistant-strain mortality estimates. Within each pathogen-drug combination, studies with multiple mortality estimates received multiple scores, which were averaged into a single study score. Then, for each pathogen-drug combination, the top three studies were selected, and their scores were averaged, thereby generating a single mean mortality score.

Selecting three studies is likely insufficient for more complex infection-site-level AMR modeling, but it enables insight into the relative strength of the most relevant literature across pathogen-drug combinations. Additionally, restricting to the top three studies effectively controls for differences in the number of studies across pathogen-drug combinations. The heat map of Figure 12 shows the mean study score for the top three resistant-strain mortality studies in each pathogen-drug combination.

Figure 12 Heat Map of Mean Study Score Among Top Three Resistant-Strain Mortality Studies

Note: gray cells correspond to pathogen-drug combinations that were not investigated.

This is a heat map with the five pathogens on the x axis and the four drug resistance phenotypes on the y axis. Each cell corresponds to a different pathogen-drug combination. The cell’s color indicates the mean score of the three highest-scoring studies with resistant-strain mortality information. The mean score is 17 for MDR A. baumannii, 15.3 for MDR E. coli, 6 for MDR E. aerogenes/E. cloacae, 8.7 for MDR K. pneumoniae, 16 for MDR P. aeruginosa, 22 for fluoroquinolone-resistant E. coli, 24 for fluoroquinolone-resistant K. pneumoniae, 22 for third-generation cephalosporin-resistant E. coli, 20 for third-generation cephalosporin-resistant K. pneumoniae, 12.3 for third-generation cephalosporin-resistant P. aeruginosa, 18 for carbapenem-resistant A. baumannii, 16.7 for carbapenem-resistant E. coli, 9.3 for carbapenem-resistant E. aerogenes/E. cloacae, 20.7 for carbapenem-resistant K. pneumoniae, and 20 for carbapenem-resistant P. aeruginosa.

Studies on fluoroquinolone resistance and third-generation cephalosporin resistance appear to have more relevant mortality estimates than other forms of resistance—despite the fact that fluoroquinolone resistance is studied at a far lower rate. Among the pathogens, E. coli and K. pneumoniae tend to have higher mean scores. Mortality studies have much lower relevance scores for three particular pathogen-drug combinations: MDR E. aerogenes/E. cloacae (mean of 6.0), MDR K. pneumonia (mean of 8.7), and carbapenem-resistant E. aerogenes/E. cloacae (mean of 9.3). Of the 15 pathogen-drug combinations, ten cross the threshold of a high-scoring study (i.e., a rounded score >15).

While this analysis is useful for comparing scores across pathogen-drug combinations, it is possible that the higher-scoring studies are infection-site-specific. Because infection-site-specific modeling is unlikely to be feasible, (see Section 5.2.3), high-scoring infection-site-specific studies may not be utilized.

This led us to a secondary analysis wherein the heat map of was adjusted to include only the top three “any infection site” studies (Figure 13). This was done because, in the absence of infection-site-specific modeling, studies about “any infection site” may be sufficiently representative of broader AMR patients to enable more generic AMR burden modeling. We found that restricting to the top three “any infection site” studies produced lower mean mortality scores.

Figure 13 Heat Map of Mean Study Score Among Top Three Resistant-Strain Mortality Studies on “Any Infection Site”

Note: gray cells correspond to pathogen-drug combinations that were not investigated.

This is a heat map with the five pathogens on the x axis and the four drug resistance phenotypes on the y axis. Each cell corresponds to a different pathogen-drug combination. The cell’s color indicates the mean score of the three highest-scoring studies with resistant-strain mortality information, when only including studies that investigated any infection site. The mean score is 10.5 for MDR A. baumannii, 12 for MDR E. coli, 6 for MDR E. aerogenes/E. cloacae, 5.5 for MDR K. pneumoniae, 6 for MDR P. aeruginosa, 0 for fluoroquinolone-resistant E. coli, 24 for fluoroquinolone-resistant K. pneumoniae, 16.5 for third-generation cephalosporin-resistant E. coli, 9.7 for third-generation cephalosporin-resistant K. pneumoniae, 12.3 for third-generation cephalosporin-resistant P. aeruginosa, 12.8 for carbapenem-resistant A. baumannii, 17.3 for carbapenem-resistant E. coli, 10.5 for carbapenem-resistant E. aerogenes/E. cloacae, 18 for carbapenem-resistant K. pneumoniae, and 17 for carbapenem-resistant P. aeruginosa.

After filtering for studies on “any infection site,” only five pathogen-drug combinations exceed the threshold for a high score (rounded score >15): fluoroquinolone-resistant K. pneumoniae, carbapenem-resistant K. pneumoniae, carbapenem-resistant E. coli, carbapenem-resistant P. aeruginosa, and third-generation cephalosporin-resistant E. coli. In the adjusted heat map of Figure 13, there are four pathogen-drug combinations in the low-scoring range (rounded score <9).

### 5.2.5 Resistant-Strain LOS across Pathogen-Drug Combinations

The procedure described in Section 5.2.3 was repeated for LOS, the other primary parameter that is required for AMR burden modeling. We scored the studies based on their resistant-strain LOS estimates and selected and averaged the top three for each pathogen-drug combination. Figure 14 presents the resulting heat map for resistant-strain LOS.

Figure 14 Heat Map of Mean Study Score Among Top Three Resistant-Strain LOS Studies

Note: gray cells correspond to pathogen-drug combinations that were not investigated.

This is a heat map with the five pathogens on the x axis and the four drug resistance phenotypes on the y axis. Each cell corresponds to a different pathogen-drug combination. The cell’s color indicates the mean score of the three highest-scoring studies with resistant-strain LOS information. The mean score is 16 for MDR A. baumannii, 15 for MDR E. coli, 0 for MDR E. aerogenes/E. cloacae, 7 for MDR K. pneumoniae, 15 for MDR P. aeruginosa, 20 for fluoroquinolone-resistant E. coli, 21 for fluoroquinolone-resistant K. pneumoniae, 21 for third-generation cephalosporin-resistant E. coli, 23 for third-generation cephalosporin-resistant K. pneumoniae, 6 for third-generation cephalosporin-resistant P. aeruginosa, 13 for carbapenem-resistant A. baumannii, 11 for carbapenem-resistant E. coli, 10 for carbapenem-resistant E. aerogenes/E. cloacae, 17 for carbapenem-resistant K. pneumoniae, and 15 for carbapenem-resistant P. aeruginosa.

Whereas 10 different pathogen-drug combinations have mean mortality scores exceeding 15, only six pathogen-drug combinations have mean LOS scores exceeding this threshold. This indicates that studies on LOS are not only less common, but also less relevant to the task of modeling AMR burden in the U.S. As explained above, the mean scores in Figure 14 do not account for the infection site and may include studies on specific infection sites, which cannot be used in more generic AMR modeling. When we limit the analysis to LOS studies on “any infection site” type (as may be required, given insufficient infection-specific literature), the mean scores decrease. This is shown in Figure 15, which presents mean scores across the top three “any infection site” resistant-strain LOS studies for each pathogen-drug combination.

Figure 15 Heat Map of Mean Study Score Among Top Three Resistant-Strain LOS Studies on “Any Infection Site”

Note: gray cells correspond to pathogen-drug combinations that were not investigated.

This is a heat map with the five pathogens on the x axis and the four drug resistance phenotypes on the y axis. Each cell corresponds to a different pathogen-drug combination. The cell’s color indicates the mean score of the three highest-scoring studies with resistant-strain LOS information, when only including studies that investigated any infection site. The mean score is 9.5 for MDR A. baumannii, 14 for MDR E. coli, 0 for MDR E. aerogenes/E. cloacae, 0 for MDR K. pneumoniae, 7 for MDR P. aeruginosa, 0 for fluoroquinolone-resistant E. coli, 0 for fluoroquinolone-resistant K. pneumoniae, 13 for third-generation cephalosporin-resistant E. coli, 10.7 for third-generation cephalosporin-resistant K. pneumoniae, 6 for third-generation cephalosporin-resistant P. aeruginosa, 11 for carbapenem-resistant A. baumannii, 10.7 for carbapenem-resistant E. coli, 10.5 for carbapenem-resistant E. aerogenes/E. cloacae, 9 for carbapenem-resistant K. pneumoniae, and 14.3 for carbapenem-resistant P. aeruginosa.

Notably, none of the pathogen-drug combinations have a mean LOS score in the high-scoring range (>15). In addition, four different pathogen-drug combinations have a score of 0 because no “any infection site” resistant-strain LOS estimates were found in the included studies.

When considering both Figure 13 and Figure 15, MDR E. coli, carbapenem-resistant P. aeruginosa tend to have higher mean scores across both mortality and LOS estimates, when restricting to the three most relevant “any infection” resistant-strain estimates. On the other hand, consistently lower mean scores were seen across both mortality and LOS for fluoroquinolone-resistant E. coli, MDR K. pneumoniae, MDR P. aeruginosa, MDR E. aerogenes/E. cloacae, and MDR K. pneumoniae. These lower scores are a result of low-scoring “any infection site” studies and a lack of “any infection site” studies—both of which suggest that the literature may be lacking in studies highly relevant to U.S. AMR burden modeling.

### 5.2.6 Extent of Agreement Among Studies

An additional metric of evaluation is the extent to which comparable estimates agree with each other. As discussed above, all studies were scored on components that would account for some of the variation between estimates. However, disagreement between studies is a broader issue that captures additional threats to generalizability. Even within a given pathogen, drug, and infection site, differences in target populations introduce variation; studies focused on post-transplant patients or patients who were already hospitalized in an ICU at the time of infection are expected to have different underlying AMR mortality rates than studies on the U.S. population in general. As another example, confounding factors can be controlled with varying degrees of success, even in cohort studies or studies with low SE. Disagreement between a set of study estimates thus can indicate a wider range of issues that threaten the validity of generalizing from those studies to the full U.S. population of AMR patients.

Accordingly, each pathogen-drug-infection site combination was evaluated for the extent of agreement among its studies (using standard deviation as the metric of agreement), and then averages were taken across pathogen-drug combinations. In this analysis, we used only resistant-strain mortality, as LOS estimates are less numerous and reported with less consistency (with some studies reporting mean LOS and others reporting median LOS). To identify the extent of agreement, we grouped studies by pathogen, drug, and infection site. Only studies with medium or high scores were included (i.e., studies whose resistant-strain mortality estimate(s) led to a rounded mean score ≥9).^27^ For any grouping of pathogen, drug, and infection site with more than one mortality estimate, we computed the standard deviation (SD) of the estimates. Then, these standard deviations were averaged across all infection sites for a given pathogen-drug combination.^28^ The resulting metric is presented in the second column of Table 14 and represents the mean variation in a pathogen-drug’s mortality estimates among medium- or high-relevance studies, averaged across well-defined infection sites.

Table 14 Extent of Agreement Among Resistant-Strain Mortality Estimates with Medium to High Scores, by Pathogen and Drug

Pathogen and Drug | Standard Deviation, Averaged over All Infection Sites | Number of Infection Sites with Multiple Estimates | Agreement Score
Fluoroquinolone, K. pneumoniae | 0.5% | 1 | 3
Cephalosporin ^[a]^, P. aeruginosa | 1.6% | 1 | 3
Carbapenem, A. baumannii | 8.7% | 1 | 3
Fluoroquinolone, E. coli | 9.7% | 1 | 3
Carbapenem, K. pneumoniae | 10.8% | 4 | 2
MDR, P. aeruginosa | 10.9% | 3 | 2
MDR, E. coli | 11.3% | 2 | 2
Cephalosporin, E. coli | 11.8% | 2 | 2
Cephalosporin, K. pneumoniae | 12.5% | 1 | 2
Carbapenem, P. aeruginosa | 14.1% | 2 | 2
MDR, A. baumannii | 18.8% | 1 | 1
Carbapenem, E. coli | 21.6% | 1 | 1
Carbapenem, Enterobacter | Could not be computed ^[b]^ | 0 | 1
MDR, K. pneumoniae | Could not be computed | 0 | 1
MDR, Enterobacter | Could not be computed | 0 | 1

[a] Cephalosporin refers to third-generation cephalosporin.

[b] In some cases, it was not possible to calculate the standard deviation between comparable estimates, because the pathogen-drug combination did not have any infection site with more than a single estimate.

Based on the standard deviation (averaged across infection sites), an agreement score was assigned. These agreement scores are presented in the final column of Table 14.

■ Agreement Score = 3 if average standard deviation >10 percent.
■ Agreement Score = 2 if average standard deviation is 10 – 15 percent.
■ Agreement Score = 1 if average standard deviation >15 percent (or could not be determined).

### 5.2.7 Overall Comparison of Pathogen-Drug Combinations

In the preceding sections, we used the following metrics to analyze the relevance of the available literature to U.S. AMR burden modeling for each pathogen-drug combination:

1. Number of distinct studies with a resistant-strain mortality or LOS estimate (Section 5.2.1).
2. Mean score of the top resistant-strain mortality studies, with and without a restriction on “any infection” type (Section 5.2.3).
3. Mean score of the top resistant-strain LOS studies, with and without a restriction on “any infection” type (Section 5.2.5).
4. Agreement score conveying the extent to which medium- or high-scoring resistant-strain mortality estimates agree (Section 5.2.6).

Item 1 was converted into a simple scale ranging from 1 to 3.^29^ Items 2 and 3 were also given a simple 1-to-3 point scale.^30^ Table 15 presents these summary quantities, along with an overall score. The overall score was calculated by summing across the row and dividing by 18, the maximum possible total.

Table 15 Overall Summary for each Pathogen-Drug Combination

Pathogen and Drug | Number of Studies | Top Mortality Estimates | Top LOS Est. ^[a]^ | Top Generic Mortality Est. ^[b]^ | Top Generic LOS Est. | Study Agreement Score | Overall Score
Carbapenem, P. aeruginosa | 3 | 3 | 2 | 3 | 3 | 2 | 89%
Cephalosporin, E. coli ^[c]^ | 2 | 3 | 3 | 3 | 3 | 2 | 89%
Cephalosporin, K. pneumoniae | 2 | 3 | 3 | 3 | 3 | 2 | 89%
Carbapenem, A. baumannii | 3 | 3 | 2 | 1 | 2 | 3 | 78%
Carbapenem, K. pneumoniae | 3 | 3 | 3 | 1 | 2 | 2 | 78%
Fluoroquinolone, K. pneumoniae | 1 | 3 | 3 | 3 | 1 | 3 | 78%
MDR, E. coli | 2 | 2 | 2 | 2 | 3 | 2 | 72%
Fluoroquinolone, E. coli | 1 | 3 | 3 | 1 | 1 | 3 | 67%
MDR, A. baumannii | 2 | 3 | 3 | 1 | 2 | 1 | 67%
MDR, P. aeruginosa | 2 | 3 | 2 | 1 | 1 | 2 | 61%
Carbapenem, E. coli | 1 | 3 | 2 | 2 | 2 | 1 | 61%
Carbapenem, Enterobacter | 1 | 2 | 2 | 2 | 2 | 1 | 56%
Cephalosporin, P. aeruginosa | 1 | 2 | 1 | 2 | 1 | 3 | 56%
MDR, K. pneumoniae | 1 | 2 | 1 | 1 | 1 | 1 | 39%
MDR, Enterobacter | 1 | 1 | 1 | 1 | 1 | 1 | 33%

[a] Est. indicates “estimates.”

[b] “Generic” indicates that the estimate is not specific to infection site and is instead based on “any infection.”

[c] Cephalosporin refers to third-generation cephalosporin.

Aggregating these qualities produces an overall score that ranges from 33 percent (MDR E. aerogenes/E. cloacae) to 89 percent (shared by third-generation cephalosporin-resistant E. coli, third-generation cephalosporin-resistant K. pneumoniae, and carbapenem-resistant P. aeruginosa). This score provides an overall comparison of how relevant the available literature is for AMR burden modeling in the U.S., accounting for total number of studies, the relevance of the strongest available studies, the capability for generic (“any infection site”) modeling, and the extent of agreement among studies.

Figure 16 plots the overall scores for each pathogen-drug combination. K. pneumoniae tend to have higher overall scores than the other pathogens, and E. aerogenes/E. cloacae generally has lower overall scores.

Figure 16 Line Plot of Overall Score for each Pathogen-Drug Combination

This is a line plot showing the overall score for each pathogen-drug combination. The x axis is the overall score, expressed as a percentage. Each pathogen-drug combination is represented as a single point on the line plot. The scores in this figure are shown in the final column of Table 15.

### 5.2.8 Susceptible-Strain Estimates

The focus of Section 5.2.7 has been on resistant-strain mortality and LOS, as these estimates are available for all studies and facilitate comprehensive analysis. However, the true modeling parameters for AMR burden are attributable mortality and attributable LOS, which are only available when a study includes a counterfactual group. In our literature review, the susceptible strain of the pathogen served as the counterfactual, such that excess values would be measured relative to the baseline mortality and LOS among susceptible infections.

In general, fewer studies report mortality and LOS associated with a susceptible strain.^31^ The 167 distinct studies contain 319 resistant-strain mortality and LOS estimates. Of these 319 resistant-strain estimates, 97—or 30.4 percent—do not have an associated susceptible-strain estimate. In cases where a susceptible estimate is available, it tends to be more precise than the resistant-strain estimate. For mortality, the susceptible-strain standard error is 1.8 percentage points lower than the resistant-strain standard error, on average. For LOS, the susceptible-strain sample size is 291 larger than the resistant-strain sample size, on average.^32^

Figure 17 presents the number of studies with susceptible counterfactual information, by drug and pathogen. Comparing against Figure 10 confirms that far fewer studies are available with susceptible-strain information, across all pathogen-drug combinations. This gap between available resistant-strain information and susceptible-strain information is largest for A. baumannii.

Figure 17 Heat Map of Number of Studies with Susceptible Strain Information, by Drug and Pathogen

This is a heat map with the five pathogens on the x axis and the four drug resistance phenotypes on the y axis. Each cell corresponds to a different pathogen-drug combination. The cell’s color indicates the number of included studies with susceptible strain information. MDR A. baumannii has 8 studies, MDR E. coli has 11 studies, MDR E. aerogenes/E. cloacae has 1 study, MDR K. pneumoniae has 5 studies, MDR P. aeruginosa has 12 studies, fluoroquinolone-resistant E. coli has 5 studies, fluoroquinolone-resistant K. pneumoniae has 2 studies, third-generation cephalosporin-resistant E. coli has 12 studies, third-generation cephalosporin-resistant K. pneumoniae has 10 studies, third-generation cephalosporin-resistant P. aeruginosa has 3 studies, carbapenem-resistant A. baumannii has 15 studies, carbapenem-resistant E. coli has 6 studies, carbapenem-resistant E. aerogenes/E. cloacae has 1 study, carbapenem-resistant K. pneumoniae has 30 studies, and carbapenem-resistant P. aeruginosa has 18 studies.

### 5.2.9 Summary of Pathogen-Drug-Level Comparisons

Large variation exists in the number of included studies per pathogen-drug combination, with some having fewer than 5 and others having more than 25. In general, we found that carbapenem resistance had more studies pertinent to AMR burden modeling than other drug resistance types. Among the five pathogens, A. baumannii and K. pneumoniae have the most studies, and E. aerogenes/E. cloacae had the fewest. However, the number of included studies and the relevance to AMR burden modeling are not always directly correlated. Moreover, even among pathogen-drug combinations with over 25 studies, we found this to be insufficient for infection-site-specific modeling.

We also compared the relevance scores of the three highest-scoring studies in each pathogen-drug combination, as an attempt to control for the unequal number of studies. However, when we further limited to the three highest-scoring “any infection site” studies—as would likely be required in the absence of infection-site-specific modeling—the relevance scores decreased substantially. To further evaluate the validity of our assumption that the included studies can be generalized to the full U.S. population of AMR patients, we determined the extent of agreement among estimates we assumed to be comparable, because differences in study populations would tend to introduce disagreement between estimates. The mean standard deviation across “comparable” mortality estimates (i.e., a single combination of pathogen, drug, and infection site) ranged from less than two percent (fluoroquinolone-resistant K. pneumoniae and third-generation cephalosporin-resistant P. aeruginosa) to over 15 percent (MDR A. baumannii and carbapenem-resistant E. coli).

Combining these factors led to an overall score for each pathogen-drug combination (see, Table 15 and Figure 16). There are no clear patterns of specific pathogens or drugs that earn higher versus lower overall scores, although MDR tends to appear lower on the scale—possibly due to wider variations in the definition and type of MDR—and carbapenem-resistance tends to appear higher on the scale.

While we have focused on resistant-strain data to characterize the pathogen-drug combinations more comprehensively, susceptible-strain data are also needed to generate estimates or projections of attributable mortality and attributable LOS. All of the issues identified above for resistant-strain data are compounded for susceptible-strain data, which are reported 30 percent less frequently in our included studies.

## 5.3 POSSIBLE PUBLICATION BIAS

In 5.1, we presented statistics on the overall state of literature available for modeling AMR burden in the U.S. In 5.2, we compared the 15 pathogen-drug combinations to assess relative capacity for national burden modeling. Next, in 5.3, we consider the extent to which estimates might be affected by publication bias. While Serra-Burriel et al. (2020) found evidence of publication bias in the case of MDR mortality (see section 2.6), our analysis of carbapenem-resistant A. baumannii and carbapenem-resistant P. aeruginosa does not provide strong evidence of that same finding.

As a case study, we analyzed the possibility for publication bias in three pathogen-drug-infection combinations. In general, publication bias is assumed to impact smaller studies, because large, well-funded studies often enjoy high rates of publication given the magnitude of their investment and likelihood of achieving statistically significant results (even by virtue of sample size alone). On the other hand, smaller studies—while often focused on important or under-studied topics—may contain larger standard errors and wider confidence intervals. This can lead to an effect where, among small studies, only those with aberrantly large effect sizes achieve statistical significance and are more likely to be published.

Exploratory modeling revealed that standard error was positively associated with resistant-strain mortality. That is, studies with more uncertainty also tended to report higher mortality rates. Given this initial finding—along with the fact that Serra-Burriel et al. (2020) detected evidence of potential publication bias among mortality estimates—we performed similar analyses as Serra-Burriel et al. (2020) for three pathogen-drug-infection site combinations with sample sizes large enough (n≥10) to generate funnel plots and perform Egger’s regression test for funnel plot asymmetry. A funnel plot is a graph of effect size^33^ against SE for a variety of publications that all estimate a common quantity. In the absence of publication bias, these graphs generally form a funnel shape. The studies with low SE tend to be closely clustered around a common mean at the top of the graph, and as SE increases (moving down the y-axis), estimates become more dispersed around the common mean. However, publication bias can selectively remove studies with high SE but low effect sizes (i.e., sometimes viewed as uninteresting, non-statistically significant results), thereby removing data points from the bottom-left portion of the plot. This can create the asymmetry characteristic of publication bias.^34^

Our analysis controlled for infection site given its impact on mortality rates. The three pathogen-drug-infection site combinations we analyzed are carbapenem-resistant A. baumannii (any infection site), carbapenem-resistant A. baumannii (BSI), and carbapenem-resistant P. aeruginosa (BSI). Their funnel plots are shown below in Figure 18, Figure 19, and Figure 20.

Figure 18 Funnel Plot for Carbapenem-Resistant A. baumannii (Any Infection Site)

This is a funnel plot comparing estimates of mortality among carbapenem-resistant P. aeruginosa infections. The graph only contains studies that investigated any infection site. There are 14 points on the plot, each representing a different study. The y axis is standard error, and the x axis is standardized mean difference. There is some asymmetry in the funnel plot, which indicates possible publication bias. However, the asymmetry is mainly due to a single 2007 study by Cai et al. that had very low standard error and a much lower mortality estimate than the other studies.

Figure 19 Funnel Plot for Carbapenem-Resistant A. baumannii (BSI)

This is a funnel plot comparing estimates of mortality among carbapenem-resistant A. baumannii bloodstream infections. There are 11 points on the plot, each representing a different study. The y axis is standard error, and the x axis is standardized mean difference. The plot does not contain substantial asymmetry.

Figure 20 Funnel Plot for Carbapenem-Resistant P. aeruginosa (BSI)

This is a funnel plot comparing estimates of mortality among carbapenem-resistant P. aeruginosa bloodstream infections. There are 10 points on the plot, each representing a different study. The y axis is standard error, and the x axis is standardized mean difference. The plot does not contain substantial asymmetry.

While the funnel plots have some deviations from the ideal symmetric shape, they do not display the typical pattern associated with publication bias. While studies with high standard error appear to be published less frequently, they are not skewed toward large effect sizes. Egger’s regression test showed that carbapenem-resistant A. baumannii (any infection site) does have a statistically significant asymmetry, with a bias of 5.5±1.1 (estimate ± SE) and a p-value of 0.0002. Although the results are statistically significant, they are strongly influenced by the estimate from Cai et al. (2017), which was one of the higher-scoring studies we found. Excluding the estimate from Cai et al. caused the p-value to rise above 0.05.

For carbapenem-resistant A. baumannii (BSI) and carbapenem-resistant P. aeruginosa (BSI)—shown in Figure 19 and Figure 20—Egger’s regression test revealed positive but nonsignificant bias, with p-values of 0.407 and 0.139, respectively. This indicates that, while some asymmetry exists, it is not statistically significant at a significance level of α = 0.05.^35^

For the statistically significant finding of carbapenem-resistant A. baumannii, other possible sources beyond publication bias may explain the asymmetry. For example, it may be the case that smaller studies were simply performed in settings or regions where mortality truly is higher.

## 5.4 OTHER MODELING PARAMETERS AND CONSIDERATIONS

The foregoing analysis in Sections 5.1, 5.2, and 5.3 focused primarily on two critical modeling parameters that were emphasized in the literature review, resistant-strain mortality and resistant-strain LOS. However, additional parameters are needed to estimate or project AMR burden based on literature. In this section, we focus on literature-related issues that complicate estimation for these other modeling parameters.

### 5.4.1 Infection Sites

Analysis of the included literature focused on four infection sites that we deemed particularly important for AMR burden modeling: BSI, UTI, SSI, and pneumonia. These four types represent a substantial majority of publications we found. When excluding multiple or unknown infection sites (“any infection site,” “other infection site,” and “undetermined” cases), BSIs, UTIs, SSIs, and pneumonia make up 88 percent of estimates based on a single, specified infection. Thus, modeling these four sites may be sufficient for capturing a substantial majority of infection-site-specific variation in mortality and LOS.

Nevertheless, while literature has focused on BSI, UTI, SSI, and pneumonia, other infection sites contribute to the total AMR burden. These other infection sites must be quantified to capture the full public health and economic impact of AMR in the U.S. For example, the literature we reviewed also included estimates for intra-abdominal infections, sterile body fluids infections, wound infections (both superficial and deep), biliary tract infections, fungal infections, genital tract infections, and skin or soft tissue infections, among others. While it is not feasible to estimate or project attributable mortality and attributable LOS for every one of these infection sites, modeling efforts may need to characterize the prevalence of other infection sites and apply generic rates in order to approximate their contributions.

### 5.4.2 Community-Acquired Infections vs. Healthcare-Associated Infections

The literature review and analysis focused on data about healthcare-associated infections. However, as discussed previously, major differences in outcomes for community-acquired infection can exist. Typically, healthcare-associated infections incur higher raw costs (Roberts, et al., 2009) and produce worse clinical outcomes (Cosgrove, et al., 2002). However, this is an area that requires further study, as confounders can greatly impact findings. Neidell et al. (2012) showed that, because healthcare-associated infections affect populations possessing far more risk factors, adjusting for confounders caused community-acquired infections to have greater excess costs, attributable LOS, and attributable mortality than healthcare-associated infections.

For example, using an uncensored linear model, Neidell et al. (2012) estimated excess hospital charges to be $8,200 for healthcare-associated infections, compared to $24,000 for community-acquired infections. They also estimated attributable LOS to be 1.1 days for healthcare-associated infections, compared to 2.8 days for community-acquired infections. While these values depend heavily on the pathogen, drug resistance, and infection site being studied, Neidell et al. (2012) showed that the impact of an adjusted analysis can reverse the associations between clinical setting and excess values.

These differences likely warrant separate modeling approaches. This is particularly true given that many studies focus on a single clinical setting, with many studies being conducted in hospitals. Estimates of attributable mortality or attributable LOS generated from these studies likely do not represent the AMR burden associated with community-acquired infections.

### 5.4.3 Representativeness of Study Populations

In some cases, studies were very clearly focused on narrow populations that do not generalize to the broader U.S. population. Issues of representativeness can pose major threats to the validity of estimates for modeling AMR burden in the U.S..

For example, Freire et al. (2015) performed a prospective cohort study on carbapenem-resistant A. baumannii (CRAB) among liver transplant patients in Brazil. Participants of the study acquired the infection prior to transplantation, and the health endpoint was 60-day mortality. Those with the resistant strain experienced a mortality rate 46.4 percent higher than the susceptible group—a result that was statistically significant. Freire et al. (2015) also reported the resistant-strain mortality for several infection sites, presented in Table 16 with 95 percent confidence intervals.^36^ For comparison, Table 16 also shows the mean CRAB mortality reported by other studies on the same pathogen, drug resistance, and infection site.

Table 16 Comparing CRAB Estimates by Freire et al. (Post-Liver Transplant Patients) to Other Studies

Infection Site | Freire et al. CRAB Mortality Estimate | 95% CI for Freire et al. Mortality Estimate | Mean CRAB Mortality Among Other Studies ^[a]^ | Difference between Freire et al. and Other Studies
Any | 71% | (58%, 83%) | 47% | +24%
BSI | 67% | (38%, 88%) | 48% | +19%
PNE | 58% | (33%, 80%) | 41% | +17%
SSI | 50% | (27%, 73%) | Not available ^[b]^ | Not available
UTI | 0% ^[c]^ | Not available | 17% | -17%

[a] For “any infection site,” the other available studies are Choi et al. (2019), de Gouvêa et al. (2012), Henig et al. (2015), Huang et al. (2012), Lemos et al. (2014), Liu CP et al. (2016), Nutman et al. (2014), Prates et al. (2011), Routsi et al. (2010), Sheng et al. (2010), Song et al. (2011), Yang et al. (2013), Chang et al. (2011), and Cai et al. (2017). For BSI, the other studies were Balkhair et al. (2019), Esterly et al. (2011), Kim SY et al. (2012), Liu Y et al. (2020), Munoz-Price et al. (2010), Papadimitriou-Olivgeris et al. (2017), Deris et al. (2011), Jamulitrat et al. (2009), and Cai et al. (2017). Kim YJ et al. (2018), discussed below as another special case, was excluded from the BSI other-study estimate. For pneumonia (PNE), the other available studies are Choi et al. (2019), Zheng et al. (2013), and Cai et al. (2017). For UTI, the other available studies are Choi et al. (2019) and Cai et al. (2017).

[b] Other studies were not available with estimates of CRAB mortality among SSIs patients.

[c] Freire et al. reported all results, including this UTI outcome, which had a sample size of 1. As the estimate is 0 percent, standard error cannot be reliably estimated.

As another example, Chaves et al. (2017) studied blood marrow transplant patients in Brazil with carbapenem-resistant P. aeruginosa (CRPA). Among patients with BSIs, Chaves et al. (2017) reported CRPA mortality of 79.0 percent, which is 32.1 percent above the mean mortality of 46.9 percent from other available CRPA BSI studies.^37^ As a final example, Kim YJ et al. (2018) studied CRAB among individuals with BSIs in Korea who underwent living donor liver transplantation. Kim YJ et al. (2018) showed that the CRAB mortality among its BSI subjects was 50.0 percent, which is extremely close to the mean estimate of 49.8 percent from other CRAB BSI estimates.^38^

When selecting studies for AMR modeling purposes, the original intent and study population must be evaluated to determine representativeness for the broader population of AMR patients.

In a study on the global burden of AMR, Pezzani et al. (2021) developed methodologies for evaluating representativeness, which potentially could be adapted to our purposes to aid in analyzing studies’ generalizability from their original purpose to the task of modeling the economic burden of AMR. For cohort studies, Pezzani et al. (2021) assessed whether the exposed cohort and non-exposed cohort were drawn from the same community. For case-control studies, Pezzani et al. (2021) considered whether cases were drawn consecutively, the extent of potential selection bias, and whether community controls or hospital controls were used. For both study designs, they reviewed the quality of records that were used to determine whether the participant experienced exposure.

22 Studies with multiple estimates were assigned multiple scores, which were subsequently averaged. This led to some studies having scores lying between the displayed tick marks. The thresholds between low scores, middle scores, and high scores are based on integer-rounded values.

23 When developing the scoring algorithm, the final enrollment year was used rather than the midpoint of the enrollment period to avoid penalizing long-running studies that collected recent data but also used longer enrollment periods to improve sample size and, likely, representativeness.

24 As before, studies containing separate estimates for distinct pathogen-drug combinations are counted multiple times. The group of 169 mortality studies and 88 LOS studies are overlapping. Of the 88 LOS studies, 76 contain mortality estimates and are included in the count of 169.

25 The nine studies with cost estimates are not included in the counts of Table 6, as they were identified through a separate search.

26 As with mortality and LOS, the ultimate parameter required for modeling burden is excess healthcare cost, which represents the additional cost attributable to AMR.

27 Lower-scoring studies were excluded because we assumed that the existing scoring metric likely already captured study elements that reduce representativeness. This exclusion removed many studies conducted in “Other” regions, primarily leaving only U.S. and European studies.

28 The infection sites included in this analysis are: BSIs, UTIs, SSIs, pneumonias, and any infection site. While the composition of infection sites included in “any infection site” may change across studies, it was analyzed as a defined, stable infection category insofar as it would be treated as such for AMR burden modeling purposes.

29 1-10 studies = 1 point, 11-20 studies = 2 points, and 21-30 studies = 3 points.

30 Low mean score (3-8) = 1 point, middle mean score (9-15) = 2 points, and high mean score (16-27) = 3 points.

31 Out of studies that only investigate a single study group, many more publications report on the resistant strain than on the susceptible strain, as the resistant strain poses a greater public health concern.

32 Across all studies (those with and without susceptible estimates), the mean resistant-strain SE is 6.4 percent. The mean susceptible-strain SEs is 3.8 percent. The mean resistant-strain LOS sample size is 126.6, and the mean susceptible-strain LOS sample size is 430.9. However, the LOS sample size distributions are heavily right-skewed; their medians are 66 and 104, respectively.

33 In this case, the effect size refers to the study’s estimated resistant-strain mortality.

34 It is important to note that there can be other causes of the asymmetry, aside from publication bias.

35 The three p-values presented in this passage are unadjusted.

36 95 percent confidence intervals were computed using the Clopper-Pearson method.

37 The other available studies for CRPA, BSI are: Aviv et al. (2018), Balkhair et al. (2019), Jeong et al. (2014), Peña et al. (2012), Suárez et al. (2010), Tofas et al. (2017), Tuon et al. (2012), Dantas et al. (2014), Papadimitriou-Olivgeris et al. (2019), and Cai et al. (2017).

38 The other available studies for CRAB, BSI are: Balkhair et al. (2019), Esterly et al. (2011), Kim SY et al. (2012), Liu Y et al. (2020), Munoz-Price et al. (2010), Papadimitriou-Olivgeris et al. (2017), Deris et al. (2011), Jamulitrat et al. (2009), and Cai et al. (2017). Freire et al. (2015) was excluded as it was identified as having a nonrepresentative study population.