# 4 METHODOLOGY

For each of the 15 pathogen-drug combinations, we first conducted a systematic review of published literature to:

■ Characterize the current state of knowledge with respect to mortality, LOS, and healthcare costs, and
■ Identify data gaps both across and within pathogen-drug combinations.

Then we evaluated studies using several metrics of relevance to the task of AMR burden modeling in the U.S. One important metric was the precision of the study estimates, which impact the uncertainty of current estimates and future projections of AMR burden. We also compared estimates across region^15^ to identify the extent to which U.S. estimates and projections could rely on data from other countries where AMR rates may differ. We analyzed studies’ enrollment periods to assess the recency of data. We considered the epidemiological design on which studies were based. By aggregating these metrics, we developed a scoring methodology that quantifies each study’s relevance to the task of AMR burden modeling in the U.S. This metric served as the basis for comparisons across and between pathogen-drug combinations.

Our analysis focused primarily on study estimates of resistant-strain parameters—specifically, mortality and LOS.^16^ However, we also considered susceptible-strain estimates, which were tended to have better precision but was investigated at a lower frequency. We evaluated the capacity for infection-specific modeling and addressed additional modeling considerations, such as publication bias, representativeness of the study populations, disease prevalence, and healthcare setting.

## 4.1 SYSTEMATIC LITERATURE REVIEW

For each pathogen-drug combination, we searched PubMed and Web of Science using Medical Subject Headings (MeSH) terms, as well as terms used to index medical journal articles or books. For example, for carbapenem-resistant K. pneumoniae (CRKP), our search string for PubMed included the following terms where “mortality” was specified both as a MeSH term and a MeSH subheading term that encompassed a range of mortality related entry terms such as “death rate” or “crude morality rate:”

( (“Klebsiella-pneumoniae”) ) AND ( (“Carbapenems”) ) AND ( (“Drug Resistance, Bacterial”[MeSH]) ) AND ( (“Length of Stay”[MeSH]) OR (“Mortality”[MeSH]) OR (“Mortality”[MeSH subheading]) OR (“Outcome Assessment, Health Care”[MeSH]) OR (“Risk factors”[MeSH]) )

For Web of Science searches, we made slight modifications to the search string as needed, such as:

Klebsiella pneumoniae AND Fluoroquinolones AND Bacterial Drug Resistance AND (Length of Stay OR Mortality OR Health Care Outcome Assessment OR Risk factors)

Our search included all types of publications (e.g., books and documents, meta-analysis) and covered the period from 2007 through 2021. The search string was adapted to the other pathogen-drug combinations by replacing the pathogen and drug class terms. After retrieving all studies for each pathogen-drug combination, we uploaded them to Rayyan, a systematic literature review platform, to remove duplicates and to screen them efficiently. After removing duplicates, we used the following step-wise approach to review studies for inclusion/exclusion:

■ Title and abstract review, and
■ Full-text review.

The title and abstract review involved defining “keywords to exclude” that allowed us to identify and exclude out-of-scope studies (e.g., studies involving pediatric patients only) and then “keywords to include” to target in-scope studies. The “keywords to include” consisted of the pathogen name and drug class along with any abbreviations and a variety of outcomes. Table 3 presents these keywords to include and to exclude, using carbapenem-resistant K. pneumoniae as an example.

Table 3 Keywords to Include and to Exclude in Rayyan, for Carbapenem-Resistant K. pneumoniae

Keywords to Include | Keywords to Exclude
Klebsiella pneumoniae; carbapenem, pneumonia, CRKP, CSKP; resistant, susceptible; outcomes; mortality, death, deaths, died; stay, length of stay, hospital stay | children; neonatal; pediatric

Filtering by these keywords categorized the literature into topic-specific groups. Rayyan highlighted the exclusion and inclusion terms which allowed us to screen studies efficiently (see Figure 1 for a sample study entry). The title and abstract review concluded by migrating all non-excluded studies into a “maybe” folder, thereby triggering a full-text review.

Figure 1 Screenshot of a Study Entry in Rayyan, with Highlighted Inclusion Keywords

This is a screenshot showing the Rayyan interface. The screenshot shows the title, abstract, and publication information for a single study. Keywords corresponding to the inputted inclusion criteria are highlighted green. There are buttons at the top allowing the user to include the study, exclude the study, or make it as “maybe include.”

For the full-text review, we retrieved the full-text PDFs of the studies where possible from Google Scholar.^17^ We then uploaded the full-text PDFs to Rayyan and reviewed each study to determine if it included data on the mortality and/or LOS of adult patients infected with the pathogen of interest and resistant to the AM drug of interest. We also screened studies for counterfactual data, reporting the same outcomes for patients infected with the pathogen of interest but susceptible to the AM drug of interest. Next, we moved all studies with the relevant data to the “include” folder in Rayyan. Further, we verified that all listed studies in the systematic review studies identified were among the “include” folder. When we found a study that was listed in the systematic review study but had not been identified in our search, we added that study to our “include” folder. When a study did not report any of the variables of interest for the pathogen-drug combination of interest or met an exclusion criterion, we removed the study from our sample, noting the reason(s) for exclusion.

A complete list of exclusion reasons is provided below.

■ Data are not specific to the target “bug-drug” combination.
■ Out-of-scope outcome variables. The study reports prevalence rates only and no mortality or LOS information.
■ Out-of-scope population. The study reports data for paediatric/neonatal patients (mostly excluded in the title abstract screen).
■ Out-of-scope study design. The study investigated isolates from fewer than three patients; or the study compares two patient groups based on the AM therapy they were treated with or the type of procedure (e.g., transplant) that caused the infection.
■ Systematic review. While we evaluated information in systematic reviews (and used those reviews to retrieve additional studies), data in the systematic review itself were excluded.

We then extracted information on the study design, enrollment period, country, setting (single vs. multicenter), site of infection (e.g., BSI, UTI), the sample size of the resistant and susceptible infection groups of patients, the LOS for the resistant and susceptible infection groups, and the mortality for the resistant and susceptible infection groups in each of the studies in our final “Include” folder. For those pathogen-drug combinations that lacked data on one or more of these variables, we consulted with an epidemiologist and implemented the following strategies to broaden the scope and fill in the data gaps:

■ For fluoroquinolone-resistant K. pneumoniae (FRKP), we included data on mortality, hospital LOS, or healthcare costs from studies on all fluoroquinolone-resistant Enterobacteriaceae.^18^
■ For K. pneumoniae, we included data on mortality, hospital LOS, or healthcare costs from studies on K. pneumoniae [underlined: or both] K. pneumoniae and E. coli [underlined: or] all gram-negative bacteria.
■ For E. coli, we included data on mortality, hospital LOS, or healthcare costs from studies of E. coli, studies of [underlined: both] K. pneumoniae and E. coli, [underlined: or] studies of all gram-negative bacteria.
■ For third-generation cephalosporin-resistant bacteria, we included data on mortality, hospital LOS, or healthcare costs from studies on all ESBL-producing bacteria.
■ For carbapenem-resistant E. aerogenes/E. cloacae, we included data on mortality, hospital LOS, or healthcare costs from studies on all carbapenem-resistant Enterobacteriaceae.
■ For third-generation cephalosporin-resistant P. aeruginosa, we included data on mortality, hospital LOS, or healthcare costs from studies on P. aeruginosa and cefepime.

We also conducted a supplementary literature review using the expanded definitions (e.g., mortality of patients with fluoroquinolone-resistant Enterobacteriaceae), where necessary, when there were fewer than 5 studies a given pathogen-drug combination.

Finally, we made the following additional assumptions based on data quality and availability:^19^

■ Crude mortality was sufficient when attributable mortality was not available.
■ We included 30-day, 60-day mortality, and all-time hospital mortality.
■ “Multi-drug resistant^20^” was equivalent to “resistant to all three classes.”
■ Total LOS was acceptable when LOS after isolating the pathogen was unavailable.

## 4.2 STUDY QUALITY SCORING

Using the data extracted from the studies, we compared the available literature across pathogen-drug combinations on relative strength for supporting AMR burden models. When modeling AMR burden, the two most critical parameters are attributable mortality and attributable LOS.^21^ These parameters can vary widely by pathogen, drug, and site of infection—whether it be BSI, UTI, pneumonia, SSI, or another. For mortality and LOS, the relevant metric is the excess amount that can be attributed to the resistant strain. In an unadjusted analysis, this excess is computed by taking the difference between estimates for the resistant-strain group and the susceptible-strain group. While these excess values are the primary focus for modeling AMR burden, the analysis of Section 5 focuses instead on the resistant strain, because many studies did not analyze a susceptible group and thus could not present excess values.

Using four basic components, we developed a scoring metric that conveys the strength of evidence and emphasizes relative differences between the various pathogen-drug combinations. The score for a given study is based on four study components, presented in Table 4.

Table 4 Scoring Methodology for Four Components

Feature of Study | 1 point | 2 points | 3 points
Final year when participants were enrolled | 1999-2006 | 2007-2013 | 2014-2020
Region where study was conducted | Other | Europe | U.S.
Precision of resistant-strain estimate ^[a]^ | Bottom tercile | Middle tercile | Top tercile
Study design | Other | Case-control study | Cohort study

[a] Precision refers to either the standard error of a resistant-strain mortality estimate, or the sample size associated with a resistant-strain LOS estimate.

In instances where a study’s feature was not determined, we assigned a score of 1. Using these four components, we computed a score for every resistant-strain mortality and resistant-strain LOS estimate that a study contained:

score = region score × ( enrollment year score + precision score + design score ) (1)

In some cases, a study received multiple scores because it presented more than one estimate (e.g., a study might present mortality for resistant-strain BSI infections, mortality for resistant-strain UTI infections, and LOS for any susceptible-strain infection). When making comparisons at the study level, we averaged multiple scores to acquire a single score per study. However, through the search process, 11 studies (out of 167 unique studies) were identified multiple times for different drug-pathogen combinations. Because these studies were associated with multiple pathogen-drug combinations, they were included multiple times when generating comparisons across pathogen-drug combinations. For consistency, these studies were also included multiple times when analyzing data at the study level (e.g., when calculating the distributions of Figure 4, below). Hence, while it was rare to find a study that generated distinct estimates for multiple pathogen-drug combinations, our analytical approach gives greater weight to such studies that achieved the equivalent research outcomes of several smaller studies.

In the scoring algorithm of Equation 1 above, the region score serves as a multiplicative factor rather than an additive term. This was done for several reasons, the most important being that studies conducted in different regions are often attempting to measure fundamentally different quantities. This is different from many of the other components on which the score was based. For example, the fact that a study might have very high standard error does not change the expected mortality rate; such a study can still attempt to measure the same value as a study with very low standard error. However, even two perfectly conducted studies with ideal precision may nonetheless measure different rates if they were performed in different countries, simply because they are not measuring the same underlying quantity and attributable AMR mortality rates can vary substantially across countries and regions (Murray, 2022).

In addition, when comparing mortality estimates for a single pathogen-drug combination and infection site, we found that the study region introduced more variation than any other variable. This large effect due to region was observed in exploratory regression modeling and is visible in Table 5, which displays the mean mortality rates for the resistant strain by country, for three illustrative combinations of pathogen, drug, and infection site:

Table 5 Illustrative Examples of Regional Disagreement among Mortality Estimates

Pathogen, Drug, and Infection Site | Mean Resistant-Strain Mortality
Pathogen, Drug, and Infection Site | U.S. | Europe | Asia ^[a]^ | South America | Middle East
Third-Generation Cephalosporin-Resistant P. aeruginosa, Any Infection | 20.2% | 17.9% | 37.8% | 48.5% | NA
Carbapenem-Resistant A. baumannii, Any Infection | 45.2% | 39.5% | 50.3% | 66.7% | 54.7%
Carbapenem-Resistant P. aeruginosa, BSI Infection | 33.3% | 35.5% | 68.3% | 57.0% | 66.7%

[a] None of the included studies were conducted in Japan.

[b] NA = not applicable

As Table 5 shows, the mortality estimates are somewhat similar for U.S. studies and European studies, but estimates are substantially higher in Asian studies, South American studies, and Middle Eastern studies.

The design score is based on accepted levels of evidence for epidemiological studies (Ascension Wisconsin Library, 2022). Because resistant pathogens tend to afflict older populations with comorbidities, controlling for factors like age and concomitant illness is critical to estimating the excess mortality or excess LOS that is attributable to the resistant pathogen. Unadjusted differences between the resistant-strain group and the susceptible-strain group may overestimate the attributable mortality or attributable LOS, as some of the difference between these groups potentially should be attributed to other factors, such as differences between the group members’ age, etc. This risk of upward bias in the parameters of interest necessitates reliance on carefully designed studies that account for differences between the resistant and susceptible infection groups. The design score is aimed at capturing (at least partially) this element of an epidemiological study.

In some cases, we found that study estimates were suitable for modeling but limited in usefulness because subjects in the study/case group were not exclusively afflicted with a single resistant pathogen. In these instances, the study was assigned a design score of 1.

The precision score conveys information about the range of an estimate, with the goal of assigning higher scores to more precise estimates (i.e., those with narrower confidence intervals). Precision was determined using the resistant-strain estimate, as not all studies included a susceptible-strain estimate or an estimate of the attributable mortality/LOS. For mortality, the metric of precision is the computed standard error (SE). To acquire comparable SE estimates across the various studies, each study’s standard error in the resistant-strain mortality was computed as sqrt(r ( 1 − r ) / n) , where r is the mortality rate and n is the sample size.

For LOS estimates, sample size served as the metric of precision because studies did not report LOS range information consistently. Some studies reported LOS quartiles, others reported LOS standard deviation, still others reported LOS maxima and minima, and many did not report any range information for LOS estimates at all. Sample size of the resistant-strain study group was used as a surrogate for precision, as it was reported much more consistently.

Precision scores were computed for each estimate that a study presented. For example, a study containing three estimates—resistant-strain mortality among BSI participants, resistant-strain mortality among UTI participants, and resistant-strain LOS estimates among any-infection participants—would receive three separate precision scores. To acquire precision scores, we separated mortality estimates from LOS estimates and computed terciles within the two lists. High precision corresponds to a small SE and large sample size.

The scoring algorithm presented in this section should be interpreted as a relevance score, as it is designed specifically to measure suitability for supporting AMR burden modeling. It is highly likely that few, if any, of the studies were conducted with this purpose in mind. It is our belief that the scores presented and discussed in this report have narrow application to analysis of models of the AMR burden in the U.S., for which these scores have been designed. The scores do not provide an accurate assessment of the studies in general, their usefulness in broader epidemiological settings, their contribution to the literature of AMR, or their success relative to the original intended research purposes.

15 Countries outside of North America were aggregated by continent or geopolitical region.

16 Studies investigating cost were far less common than those investigating mortality or even LOS. For this reason, studies containing cost information are analyzed separately in Section 5.1.9.

17 Studies for which we were unable to obtain full texts were labeled “not available.”

18 For example, if there were very few studies that investigated patients infected with Klebsiella pneumonia resistant to fluoroquinolones (FRKP), then we expanded the FRKP definition to also include patients infected with any Enterobacteriaceae resistant to fluoroquinolones, assuming that the outcomes of these infections would be applicable to FRKP.

19 Any attempt to model AMR burden must address the issue of how mortality is defined and the implication this has on interpreting the model’s results. For our purposes of the systematic review, all three definitions of mortality were included to capture and characterize the literature broadly, without making modeling assumptions about how to define mortality.

20 Multi-drug resistance is commonly defined as “resistance to at least one drug in at least three antimicrobial classes.” We used “multi-drug resistant” or “MDR” in our search logic for these pathogen-drug combinations.

21 While not included in our analysis, another useful metric would be whether studies used appropriate statistical methods to adjust estimates for time-dependent biases.