# 3 STUDY OBJECTIVE

Understanding the impact of AMR on the health and economy of the U.S. is critical to create effective policy. This understanding must be based on estimates or projections of AMR burden in the U.S. that are accurate and, when possible, supported by the scientific literature. Our primary objective for this study is to assess the availability and quality of published estimates of mortality, LOS, and healthcare costs associated with selected bacterial infections with resistance to one or more AM drugs. These variables are key for modeling the economic burden of AMR in the U.S. and depend heavily on pathogen, AM drug resistance, and infection site. We selected a total of 15 pathogen-drug combinations (Table 2) and four primary infection sites—BSIs, UTIs, pneumonia, and SSIs^14^—to focus on based on discussions with CDC and ASPE.

Table 2 Included Pathogen-Drug Combinations

Pathogen | Antimicrobial Drug Class | CDC Threats Report Designation | WHO Pathogen Priority List
A. baumannii | Carbapenems | urgent | critical
A. baumannii | MDR ^[a]^ | urgent
E coli | Carbapenems | urgent | critical
E coli | Cephalosporins
E coli | Fluoroquinolones | serious | critical
E coli | MDR | urgent
K. pneumoniae | Carbapenems | urgent | critical
K. pneumoniae | Cephalosporins
K. pneumoniae | Fluoroquinolones | serious | critical
K. pneumoniae | MDR | urgent
P. aeruginosa | Carbapenems | serious | critical
P. aeruginosa | Ceftazidime | serious
P. aeruginosa | MDR | serious
E. aerogenes/E. cloacae | Carbapenems | urgent | critical
E. aerogenes/E. cloacae | MDR | urgent

[a] As discussed below, in Section 4, we defined multi-drug resistant as resistance to all three classes (carbapenems, cephalosporins, and fluoroquinolones).

14 While bacterial infections are possible at other body sites, such as bone, peritoneal cavity, etc., we did not find any published studies that reported mortality, LOS, or healthcare costs for these types of infections.