# 2 CHARACTERIZING LITERATURE ON PARAMETERS FOR AMR BURDEN MODELING

Issues arise when attempting to define and estimate model parameters; impacts with broad scope can be challenging to estimate accurately. Current literature has explored some of these difficulties, which are presented below.

## 2.1 MORTALITY AND MORBIDITY RATES

Many of the issues discussed in Section 1 apply to estimates and projections of attributable mortality and morbidity, including differences in underlying data and in estimation methodologies. In general, many burden models aim to use information from multiple published sources, aggregating across pathogens, AM drugs, geographies, etc. For national estimates or projections, this type of aggregation may be essential, as many studies only estimate mortality or morbidity associated with resistance to a single AM drug, a single organism, or a certain infection site. However, certain challenges, discussed below, can lead modelers to (a) rely more heavily on a smaller number of sources or (b) narrow their focus, for example, limiting burden estimates or projections to specific regions, pathogens, or drug resistances.

Modeling AMR mortality requires estimating the number of resistant infections. Several data sources are available for this purpose, but each has limitations. For example, Burnham et al. (2019) used death certificates to estimate deaths attributable to multi-drug resistance. As the authors were aware, death certificates do not always correctly identify the cause of death, particularly when there are multiple conditions at the time of death. Moreover, death certificates are often completed by an individual who was not involved in the patient’s care (Direk Limmathurotsakul, et al., 2019). Burnham et al. (2019) addressed this issue by introducing and justifying additional assumptions, for example, about resistance rates and the proportion of death certificates that are incorrectly or incompletely indexed.

Efforts to aggregate AMR-attributable mortality and morbidity across multiple studies are complicated by overlap in resistance classes. Rossi et al. (2019) investigated carbapenem-resistant A. baumannii infections in a teaching hospital in Brazil and found most of the infections were also multidrug resistant (94 percent) or extensively drug resistant (42 percent). It is difficult to define mortality rates consistently across studies when multiple researchers could potentially assign an infection to more than one resistance class. This calls into question the validity of pooling estimates from multiple studies and may lead to reliance on fewer sources when modeling current or future AMR burden. Overlapping resistance classes also make it challenging to aggregate estimates of mortality and morbidity from different pathogen-drug combinations (e.g., summing deaths due to MDR K. pneumoniae and due to carbapenem-resistant K. pneumoniae) or evaluate trends over time for specific pathogen-drug combinations. The more publications a model relies on, the greater the possible risk of counting the same infection multiple times in resistance classes that are intended to be non-overlapping.

Another challenge with generating national estimates of attributable mortality and morbidity is that study populations are not always generalizable to the broader U.S. population. Research has found that attributable mortality depends heavily on age, sex, and healthcare setting (Cassini, et al., 2019). Discrepancies in demographics between the study population and the broader U.S. population introduce bias into burden estimates. This may be particularly relevant for models that rely on smaller studies that were not designed to be nationally representative. A study sponsored by Becton Dickinson and Tetraphase Pharmaceuticals^10^ determined that hospital characteristics (size, urban vs. rural, medical school affiliation) and geographic region were associated with significant differences in resistance prevalence in Enterobacteriaceae and Acinetobacter spp. isolates. These differences may explain some discrepancies between published resistance and burden estimates, especially among studies that are limited in geographic coverage or hospital types (Gupta, et al., 2019).

Morbidity rates are prone to many of the same challenges as mortality rates. Studies can be biased toward higher estimates of morbidity if they contain a disproportionately large number of male participants or adults over the age of 65 (Cassini, et al., 2019) (Goldstein, et al., 2019). Different assumptions and methodologies raise issues when attempting to make comparisons or aggregate findings from multiple studies into a single burden model with consistent assumptions and interpretable findings.

## 2.2 LENGTH OF STAY AND TREATMENT DURATION

There is general agreement that resistant infections lengthen patients’ LOS and treatment duration relative to susceptible infections. However, the impact of these extended stays on burden is an area of debate. The burden due to extended and costly hospital stays is, at times, difficult to quantify and may have less research than exists on attributable mortality. As seen previously, the landscape of pathogens, AM drugs, etc. tends to introduce substantial variation into estimates of the LOS attributable to AMR.

Naylor et al. (2019) found that hospital LOS was only greater by 0.8 days in E. coli infections resistant to at least one AM drug, compared to susceptible infections. However, the authors also found that the attributable LOS depends on the AM drug(s) to which the infection is resistant. Results from a meta-review by Serra-Burriel et al. (2020) agreed with these findings, showing that, overall, LOS was significantly longer in MDR healthcare-associated infections compared to non-MDR healthcare-associated infections. Roberts et al. (2009) found significantly increased hospital LOS (as well as costs) for patients with resistant infections compared to those without a resistant infection.

Despite these findings, some researchers have taken the position that the extended stays do not create additional burden. Taheri et al. (2000) argue that reducing LOS for hospitalized patients produces minimal savings in direct costs because costs are concentrated at the beginning of patient stays, and much of hospitals’ costs are overhead costs that remain fixed regardless of a patient’s LOS. Nonetheless, while the extended stays may not generate substantial additional costs to hospitals, LOS can still create additional costs for patients or insurers, who often pay several times the actual cost per day.

## 2.3 DIRECT COSTS OF RESISTANT AND SUSCEPTIBLE INFECTIONS

Resistant infections increase hospital costs to patients and insurers through several mechanisms, the most notable of which is increased LOS (discussed in Section 2.2). Costs also increase due to inpatient services such as additional drugs, laboratory tests, and imaging (Filice, et al., 2010), as well as patient isolation measures (Engler-Hüsch, et al., 2018). Of these direct costs, extended LOS is generally the most straightforward to quantify when estimating burden, as illustrated by Naylor et al. (2018), which used reference costs for National Health Service (NHS) hospitals in the UK to estimate the burden of resistant strains of E. coli bacteremia.

Wozniak et al. (2019) reviewed estimates of economic burden of AMR from 14 studies in multiple countries and found estimates varied widely across the studies and across organisms.^11^ The authors noted that appropriate study design and analysis were available for just three types of BSIs; they were unable to generate robust estimates of societal costs, as only two studies provided this information (Wozniak, et al., 2019). This points to a relative lack of literature on attributable costs compared to attributable mortality or attributable LOS.

Thorpe et al. (2018) conducted a very wide-ranging study on costs in the U.S. based on a nationally representative sample that spanned annual data from 2002 through 2014. They estimated that resistance added $1,383 to the cost of treatment of an infection, amounting to $2.2 billion in the U.S. annually. For infections other than UTIs (which tend to be less severe than many other infection sites), the incremental cost of a resistant infection is $2,656. Further, costs may depend on the type of resistance. Morales et al. (2012) studied hospital costs associated with P. aeruginosa infections and found that resistant and MDR infections were significantly more expensive than susceptible infections (Morales, et al., 2012).

## 2.4 INDIRECT COSTS OF SECONDARY BURDEN

In addition to direct hospital costs, there are additional, indirect costs associated with AR pathogens, which are referred to collectively as the secondary burden of AMR. Smith and Coast (2012) argue that much of the cost of AMR is due to these secondary effects, especially in the case of multi-drug and extensively drug-resistant infections. Shrestha et al. (2018) estimated that, in the U.S., indirect costs were more than ten times the direct costs.^12^ Although more difficult to capture and quantify, we discuss several sources of secondary burden below.

Many medical procedures, particularly surgeries and cancer treatments, prescribe AM drugs prophylactically to prevent infection. AMR threatens these procedures by reducing the efficacy of such preventative measures and elevating the risk of serious infection. Teillant et al. (2015) calculated that a reduction in AM prophylaxis efficacy of 30 percent would result in 6,367 additional infection-related deaths annually in the U.S. This projection only accounted for seven procedures (including cancer chemotherapy but excluding Caesarean sections) for which prophylactic AM drugs are established to be effective.

Another secondary effect of AMR is the economic impact of reduced productivity due to worker death, disability, time away from work, and increased care responsibilities upon the labor supply. Assuming a resistance rate of 40 percent, Taylor et al. (2014) calculated that 40 years of accumulated loss of workers would lower global GDP by 0.51 percent, equivalent to annual losses of $1.65 trillion in 2011 USD.^13^ This model only considered three infectious diseases (HIV, tuberculosis, and malaria) and hospital-acquired infections from three bacteria (E. coli, K. pneumoniae, and S. aureus) (Taylor, et al., 2014).

C. difficile, while not itself an AM pathogen, contributes to the secondary burden of AMR. Colonization with C. difficile is common across the population, but normally only causes infection when other gut microbes are killed by AM drugs. As such, overuse of AM drugs has increased incidence of C. difficile, leading to an estimated 29,300 deaths (Lessa, et al., 2015) and 476,400 cases (Guh, et al., 2020) in the U.S. in 2011 and an estimated 12,800 deaths (CDC, 2019) and 462,100 cases (Guh, et al., 2020) in the U.S. in 2017.

Michaelidis et al. (2016) estimated the aggregated downstream societal cost of AMR on a per-prescription basis for ambulatory antibiotics. These costs accounted for hospital costs, as well as first- and second-line outpatient AM drug costs. The authors estimated downstream societal costs to be $13 per AM prescription, with a range of $3-$95 (Michaelidis, et al., 2016). The wide range for these costs shows how sensitive such cost estimates can be to the model assumptions.

The secondary burden associated with these and other indirect costs is difficult to quantify in aggregate and has large associated uncertainties. Omitting secondary burden underestimates the true cost associated with AMR; however, including secondary burden leads to estimates with wide ranges and may require assumptions for which evidence is lacking.

## 2.5 SELECTING A COUNTERFACTUAL

A crucial distinction between different estimates of the burden of AMR is the counterfactual—that is, whether to compare the impact of an AMR infection to a susceptible strain of the disease or to a case with no infection (Dunachie, et al., 2020). The “no-infection” counterfactual estimates the total harm of resistant infections, whereas the “susceptible infection” counterfactual estimates the incremental harm due to an infection being resistant (de Kraker & Lipsitch, 2021). As a result, no-infection counterfactuals produce substantially larger burden estimates. Research is mixed on which is more appropriate, but as the selection of counterfactual is highly consequential for burden estimates, we discuss the two choices in detail, below.

As de Kraker & Lipsitch (2021) explain, both counterfactuals have been utilized and supported through evidence. Studies that select the susceptible-infection counterfactual do so on the assumption that resistant strains and susceptible strains compete with one another, such that successful suppression of a resistant strain would lead to an increase in the susceptible strain. In contrast, the no-infection counterfactual assumes that resistant strains add altogether new instances of infection rather than replacing the existing susceptible infections. In most cases, the question of whether the resistant and susceptible strains compete cannot be answered through the available medical or microbiological evidence. Instead, researchers compare time-series trends in the number of susceptible and resistant infections to show whether increasing prevalence of the resistant strain is met by decreasing prevalence of the susceptible strain. For example, Thorpe et al. (2018) conducted a nationally representative study with data from 2002 through 2014 and concluded that the number of bacterial infections in the U.S. remained roughly constant despite resistant infections increasing from 5 percent in 2002 to 11 percent in 2014 (Thorpe, et al., 2018). This is support for using the susceptible counterfactual; in order for the overall infection count to have remained constant, the number of susceptible infections must have decreased.

de Kraker & Lipsitch (2021) argue that the correct choice of counterfactual is dependent on the intervention being considered. When evaluating new antibiotics, “the potential impact is most clearly related to the question of how much worse the outcome of [a resistant] infection is than the outcome of [a susceptible] infection.” This supports the use of a susceptible counterfactual. On the other hand, when considering prophylactic antibiotic use during surgery, the no-infection counterfactual is more relevant, since an antibiotic that is successful against the resistant strain would prevent susceptible infections.

Whereas many studies treat the counterfactual as a single, dichotomous choice, de Kraker & Lipsitch (2021) advocate for generating estimates using both counterfactuals. The susceptible infection counterfactual generally produces lower burden estimates, since the harm from the resistant strain is measured against the harm produced by the susceptible strain. Accordingly, the susceptible counterfactual and no-infection counterfactual can provide lower and upper bounds, respectively, on the estimated burden.

## 2.6 BIAS IN PUBLISHED ESTIMATES

A literature review by Serra-Burriel et al. (2020) found evidence of publication bias in mortality estimates of multi-drug resistance. In general, the effect of higher standard error is to cause estimates to become more widely dispersed around a common mean. When publication bias exists, less precise studies are selectively published only when they achieve higher effect sizes. This produces an asymmetric funnel plot. Serra-Burriel et al. performed a funnel plot analysis and found that studies with higher standard error tended to have higher estimated mortality rates. This asymmetry in the funnel plot was statistically significant and suggests that, among less precise studies, higher mortality rates may lead to higher rates of publication. No bias was found for cost or LOS (Serra-Burriel, et al., 2020).

10 The study used data from a BD database of 375 hospitals.

11 This same result was also found by Nelson et al. (2021), a very large study of inpatient stays in the Department of Veterans Affairs healthcare system, conducted between January 2007 and October 2015. Nelson et al. also found that costs vary between healthcare-associated infections and community-associated infections.

12 Shrestha et al. (2018) studied five resistant infections in the U.S. and Thailand. The authors found that cumulative costs of treatment varied by infecting organism and by drug class.

13 This finding is similar to that of Smith et al. (2006), who modeled macroeconomic effects of MRSA and estimated that changes in labor supply and productivity would cause real GDP to fall by 0.79 percent and unemployment to increase by 8.59 percent.