# 1 INTRODUCTION

Since the discovery of penicillin in 1928, antimicrobial (AM) agents have been used to treat first bacterial and then fungal infections in humans and animals (Aslam, et al., 2018). Resistance to these agents can begin to develop immediately upon release of a new drug, and in some cases even before a drug’s release in U.S. markets (e.g., fluconazole was FDA approved in 1990, two years after fluconazole-resistant Candida was first identified) (CDC, 2019). Antimicrobial resistance (AMR) makes infections more difficult or impossible to treat, can require use of more expensive treatments or treatments with more side effects, and poses an economic burden. AMR also jeopardizes the use of healthcare procedures that carry higher risk of infection in general (e.g., organ transplants, some surgeries), as the possibility that an associated infection may be resistant increases the associated risk (CDC, 2019). AMR is a concern not only for bacterial infections, but also for fungal infections, as only three classes of antifungal drugs are available for Candida and Aspergillus infections (CDC, 2019).

Although the development of resistance to AM drugs in microorganisms is a natural process, the overuse of AM drugs in humans and animals has caused AMR to grow. Because the development and spread of AMR is driven by exposure to AM drugs, inappropriate uses—such as use with a target that is already resistant, use of the wrong dose or duration, and overuse (in healthcare and in agriculture)—can contribute to the development of AMR. Based on limited data from nursing homes, the CDC reported in 2017 that over half of all nursing home residents receive antibiotics each year, and “up to 75 percent of antibiotics prescribed in nursing homes are prescribed incorrectly,” including use of an antibiotic when none is needed, as well as incorrect antibiotic choice, dose, or duration (CDC, 2017). In hospitals, over half of patients receive antibiotics for at least one day (CDC, 2017).

AM treatments for infections are grouped into classes based on the drug’s mechanism of action. AM treatments are also designated as first-line treatments, second-line treatments, etc., depending on when they are typically used, although these designations can vary by facility, region, infection type, and patient characteristics. First-line antibiotics are recommended as the first treatment against an infection due to high effectiveness with minimal side effects or other harms. Second- and third- line treatments are less preferred either due to lower efficacy, worse side effects, greater propensity to contribute to AMR, or other harms (CDC, 2019). Chemicals in the same class have similar chemical structures and act on target organisms in the same way, so organisms that develop resistance to one drug in a class usually also gain resistance to other drugs in that class. The strength of resistance is often classified using the following categories.

■ Multi-drug resistant (MDR): resistant to at least one agent in more than two available class of AM treatments (Kadri, et al., 2018).
■ Extensively-drug resistant (XDR): only susceptible to a maximum of two AM classes and resistant to all other classes (CDC, 2019) (Kadri, et al., 2018).
■ Pan-resistant infections (PDR): resistant to all available AM treatments (CDC, 2019).

The categorizations of MDR, XDR, and PDR indicate increasing resistance to more types of AM agents. In addition, infections might also be described as difficult-to-treat (DTR), denoting resistance to all first-line AM agent classes (Kadri, et al., 2018). Infections that can be treated effectively by the recommended dosage and standard AM regimen are called susceptible (CDC, 2019). Infections that are MDR, XDR, or DTR can have negative impacts on patient outcomes and costs. For example, Kadri et al. found DTR gram-negative BSIs had 40 percent higher adjusted mortality risk than patients with susceptible gram-negative BSIs (Kadri, et al., 2018).

In the U.S., AMR threats are prioritized by CDC (CDC, 2019). Global threats requiring more research, discovery, and development of AM drugs are listed by the World Health Organization (WHO). Table 1 compares WHO’s global priority pathogen list (PPL) to CDC’s threats list. The CDC and WHO AR threat designations are shown below, in descending order from most serious:

■ CDC AR threat designations: Urgent, Serious, Concerning, and Watch List
■ WHO AR threat designations: Critical, High, and Medium

There is reasonable correspondence between the criteria for establishing threats. Urgent and Critical indicate the highest levels of threat, and Concerning and Medium indicate important but less urgent levels of threat. While there is much overlap in the criteria for identifying AR threat designations, WHO’s PPL was designed to guide research, discovery, and development of new AM drugs for top pathogens of concern, whereas CDC’s threat list categorizes pathogens based on human health concerns and projected incidence. For example, WHO’s AR threat designations account for whether there is a lack of new antibiotics in the R&D pipeline, while CDC’s designations are based on 10-year projections of incidence. Some pathogens of serious concern in the U.S., including two categorized as “urgent,” are not included in WHO’s top priorities for research globally, and all but two of the WHO PPL pathogens are included as pathogens of concern on CDC’s threat list.^7^ Note that CDC also lists three fungi not considered by WHO, and Clostridioides difficile (C. difficile) as pathogens of concern.

Table 1 Comparison of CDC’s 2019 Antibiotic Resistance Threats List and WHO’s 2017 Global Priority Pathogen List (PPL)

Pathogen | Resistance | CDC Threat Level ^[a]^ | WHO Threat Level ^[b]^
Acinetobacter | Carbapenem | Urgent | Critical
Candida auris (fungus) | - | Urgent | NA ^[c]^
C. difficile ^[d]^ | - | Urgent | NA
Enterobacteriaceae | Carbapenem | Urgent | Critical
Neisseria gonorrhoeae | Any | Urgent | High (cephalosporin resistance, fluoroquinolone resistance)
Campylobacter | Any | Serious | High (fluoroquinolone resistance)
Candida (fungus) | Any | Serious | NA
ESBL-producing Enterobacteriaciae | Beta-lactams | Serious | Critical
Enterococci | Vancomycin | Serious | High (specifically, Enterococcus faecium)
P. aeruginosa | MDR | Serious | Critical (carbapenem resistance)
Nontyphoidal Salmonella | Any | Serious | High (fluoroquinolone-resistant Salmonellae)
Salmonella serotype Typhi | Any | Serious | High (fluoroquinolone-resistant Salmonellae)
Shigella | Any | Serious | Medium (fluoroquinolone resistance)
Staphylococcus aureus | Methicillin | Serious | High (Methicillin-resistant, vancomycin intermediate and resistant)
Streptococcus pneumoniae | Any | Serious | Medium (penicillin non-susceptible)
Mycobacterium tuberculosis | Any | Serious | Considered an established priority
Group A Streptococcus | Erythromycin | Serious | NA
Group B Streptococcus | Clindamycin | Serious | NA
Aspergillus fumigatus (fungus) | Azole | Watch List | NA
Mycoplasma genitalium | Any | Watch List | NA
Bordetella pertussis | Any | Watch List | NA
Helicobacter pylori | Clarithromycin | NA | High
Haemophilus influenzae | Ampicillin | NA | Medium

[a] CDC uses the following AR threat designations: Urgent, Serious, Concerning, and Watch List.

[b] WHO uses the following designations: Critical, High, and Medium.

[c] NA = Not applicable and is used when the agency did not include a given pathogen on its list. WHO did not consider fungal infections.

[d] C. difficile is a species of bacteria that can cause disease when patients take broad-spectrum antibiotics. Many people may be colonized with C. difficile and then become infected when antibiotics kill off competing susceptible bacteria. C. difficile is not considered a drug-resistant pathogen but can thrive when competing bacteria are killed. Some patients get better by terminating broad-spectrum antibiotics, while others need to be treated with another antibiotic (CDC, 2021).

## 1.1 ESTIMATES OF NUMBER OF AMR INFECTIONS

Countries including the U.S. have developed surveillance systems to monitor, track, and identify trends in infections and AMR. Surveillance systems may be designed to identify emerging threats (such as new AMR infections), to track trends in existing infections, or to prevent infections (e.g., by identifying contaminated food products or identifying hospital patients requiring stronger containment measures). Surveillance systems are discussed in greater detail in Appendix A.

No surveillance networks collect universal data on a full population for all potentially relevant variables. As a result, estimates must be generated based on samples from surveillance systems and other data collections, and these estimates can vary based on input data, assumptions made, and estimation methods. A 2018 review article found that different burden calculation methodologies sometimes resulted in large differences in burden estimates (Naylor, et al., 2018). The underlying data sources are prone to measurement difficulties, such as the possibility of asymptomatic carriage (colonization), which can lead to false positives in patients who have been colonized but do not have an infection. Different protocols are used to test different organisms, which can limit laboratories’ ability to test for all drug-resistant organisms (Dunachie, et al., 2020), potentially skewing certain datasets toward specific pathogens.

Some of the key factors that contribute to this variation in reported AMR infections include differences in:

■ Definition of resistance.
■ Estimation techniques and underlying data sources.
■ Healthcare-associated versus community-acquired infections.
■ The extent to which time-dependent biases are accounted for.

Definition of Resistance. Differences in the definition of resistance can cause differences in estimates of AMR. Microbiological tests include measurement of minimum inhibitory concentration (MIC), which is the minimum concentration of a drug needed to inhibit an organism’s growth, or antibiotic disk diffusion susceptibility testing, in which the size of the zone of inhibition around the disk is an indirect measure of antimicrobial susceptibility. MICs and disk diffusion zone values are interpreted against breakpoints to determine whether an organism is considered resistant or susceptible.^8^ Breakpoints are organism-specific but can be updated over time, and different organizations sometimes publish different breakpoints given, for example, different definitions of the susceptibility categories.^9^ This can result in the same organism being characterized as resistant when using one set of breakpoints or characterized as intermediate or susceptible if using different breakpoints (Humphries, et al., 2017).

Estimation Techniques and Underlying Data. The impacts of different estimation techniques and data sources are illustrated in the example of CDC’s 2013 and 2019 Antibiotic Resistance Threats Reports (CDC, 2019). In the 2019 report, CDC updated certain estimation methods and recalculated its 2013 estimates using new data sources that were not available in 2013. This resulted in an almost two-fold increase in the original death estimate of the 2013 report, illustrating the impact of the underlying data sources on the final estimates. CDC’s burden estimate for drug-resistant Campylobacter provides an illustrative example of the number and type of assumptions required to estimate infections and deaths. As detailed in its 2019 report, CDC’s estimate is based on an estimate of total Campylobacter infections and deaths multiplied by average resistance prevalence for Campylobacter. The average resistance prevalence was based on the National Antimicrobial Resistance Monitoring System (NARMS) isolate data, which classified resistance by applying the European Committee on Antimicrobial Susceptibility Testing (EUCAST) cutoff values to MIC data. For Campylobacter, cutoff values are available for two species which constitute approximately 98 percent of Campylobacter infections tested by NARMS, but cutoffs were not available for other species, so those were assumed to have the same resistance rate as the two available species. For some pathogens, case counts are based on surveillance covering a portion of the U.S. population. For example, surveillance for Group A Streptococcus is performed through a network of 10 sites covering approximately 34 million people (CDC, 2019). This is just one example of the many different data sources, estimates, and assumptions required to estimate the number of one type of AMR case.

Healthcare-associated versus Community-acquired Cases. There may be significant differences in true community-acquired cases compared to healthcare-associated cases. For example, in healthcare facilities, AM drug use is common and applies a constant selective pressure for resistance. In the community, these pressures are lower, so resistant bacteria must be able to compete with susceptible bacteria, presumably preventing spread of resistance genes that have a fitness cost to the bacteria. Therefore, resistance profiles in communities may be very different than resistance profiles in healthcare settings, complicating efforts to extrapolate trends measured in healthcare settings. Typically, more data are available on healthcare-associated infections (HAIs) and infections requiring hospitalization than on community-acquired infections. However, it can be difficult to accurately assess whether a case is community-acquired or healthcare-associated. Community-acquired cases are sometimes misclassified as HAI due to delays in symptom onset or testing. Alternatively, cases may be classified as community-acquired instead of healthcare-associated in cases where a patient was exposed and colonized with an organism in a healthcare setting with significant delay prior to onset of infection (van Duin & Paterson, 2016).

Accounting for Time-Dependent Biases. With community-acquired infections, attributable LOS is simply the total length of the hospital stay, which occurs in its entirety after infection by the resistant strain. With hospital-associated infections, only a portion of the hospital stay is attributable to the infection, and this is true for both the resistant group and the comparison group. Literature has shown that treating infection as a time-fixed variable, and comparing total LOS between the resistant group and the comparison group, is an insufficient approach that tends to lead to upwardly biased estimates of the excess LOS attributable to the resistant strain (Nelson, et al., 2015; Pouwels, et al., 2020; de Kraker & Lipsitch, 2021). Several methods exist for modeling LOS more suitably. These include matching members of the resistant group with members of the comparison group based on uninfected patient-days (de Kraker & Lipsitch, 2021), performing weighted Kaplan-Meier survival analysis based on inverse probabilities (Pouwels, et al., 2020), and applying multistate models with infection status as a time-varying quantity (Nelson, et al., 2015). The validity of AMR-attributable LOS estimates depends on the extent to which studies adjust for these time-dependent biases.

## 1.2 TEMPORAL AMR TRENDS

Recent trends in AMR in the U.S. can be examined by comparing CDC’s 2019 AR Threats Report to their 2013 report (CDC, 2019). Overall, the 2019 report emphasizes that the burden of AMR is higher than previously thought. Nonetheless, the 2019 report shows that deaths have declined since 2013. CDC lists most AMR threats at the same urgency level in the 2013 and 2019 AR Threats Reports. However, there are some notable changes.

In the 2019 report, CDC identified five urgent threats, 11 serious threats, two concerning threats, and three watch list organisms. Of these, one urgent threat, one serious threat, and one watch list organism are fungi; the other 18 threats are bacteria (CDC, 2019). The fungus C. auris was added as an urgent threat (the highest threat level). Some strains of C. auris have been identified that are resistant to all three available antifungal treatments. Carbapenem-resistant Acinetobacter was upgraded from a serious threat to an urgent threat due to the lack of AM treatments and the emergence of easily-spread genetic material that allows resistance in Acinetobacter to be transferred to other bacteria. Vancomycin-resistant Staphylococcus aureus, listed as a concerning threat in 2013, was removed from the list because only isolated cases have been identified, and spread between patients has not been documented.

The 2019 urgent threats are: carbapenem-resistant Acinetobacter, Candida auris, C. difficile, carbapenem-resistant Enterobacteriaceae, and drug-resistant Neisseria gonorrhoeae. Cases of carbapenem-resistant Acinetobacter and C. difficile decreased from 2013 to 2017. Cases of drug-resistant C. auris have increased, and resistance to many antibiotics has increased in N. gonorrhoeae. Cases of carbapenem-resistant Enterobacteriaceae have increased, though containment strategies have prevented further spread of some CRE strains (CDC, 2019).

Globally, there tends to be broad variation in AMR trends. Gelband et al. (2015) reviewed trends in AMR across many countries and found that trends were organism- and country-specific. For example, methicillin resistance in Staphylococcus aureus has recently declined in the U.S., Canada, and European countries, but is rising in India and Latin America. Regional differences in healthcare, spread, at-risk populations, and background health all impact the attributable mortality rates and attributable LOS.

## 1.3 PROJECTIONS OF AMR

There have been several attempts to model AMR infections into the future using different modeling strategies. Autoregressive integrated moving average (ARIMA) and regression models, among other frameworks, have all been used to project AMR trends into the future.

Several studies employed regression models to predict future resistance trends (Soucy, et al., 2019; Durham, et al., 2010; Alvarez-Uria, et al., 2018). These studies use percent resistance of a pathogen-drug combination as the response variable as it represents the proportion of pathogen isolates that are resistant to the AM drug. Two studies used data from the large-scale surveillance networks, EARS-Net and ResistanceMap (Durham, et al., 2010; Alvarez-Uria, et al., 2018). The third study used data from three hospitals in Quebec, Canada, between 2010 and 2017 (Soucy, et al., 2019), though this study did not explicitly predict future trends. Durham et al. (2010) modeled future trends in fluoroquinolone-resistant E. coli from 2001 to 2013 using data from EARS-Net between 2001 and 2007. Durham et al. modeled trends in 18 different countries in the European Union as well as in the U.S. Predicted trends increased until 2013 in every country. Alvarez-Uria et al. (2018) modeled the trends of E. coli and K. pneumoniae globally to 2030 based on data collected from 2005 to 2015. While E. coli resistance to third-generation cephalosporins and carbapenems increased over the study period, they projected K. pneumoniae resistance to third-generation cephalosporins to decrease, despite resistance increasing to carbapenems.

Other studies used time-series analysis methods to project future trends using ARIMA models (Monnet, et al., 2001; Lopez-Lozano, et al., 2000; Willmann, et al., 2013). All three of these studies used resistance data from a single healthcare facility over 8.5 years on average (range: 7.5-10 years). Willmann et al. (2013) used quarterly resistance data to predict how past multi-drug and extensively-drug resistant P. aeruginosa would change with the introduction of a stewardship intervention that decreased drug use (Willmann, et al., 2013). Monnet et al. (2001) used AM drug use to model P. aeruginosa resistance, while Lopez-Lozani (2000) used a similar method to use the current resistance level while predicting the following year of resistance data. The key aspect of these models is that resistance is stochastic over short intervals of time.

There were several other methods employed to predict future resistance levels. One study, prompted by rising resistance levels of Neisseria gonorrhoeae, used stochastic methods to generate simulations of transmission to estimate the impact of a vaccine on prevalence (Craig, et al., 2015). Alawieh et al. (2015) created a computational framework that utilizes the EARS-Net data to predict resistance rates one or two years into the future. Blanquart et al. (2017) created a mathematical framework to measure the seasonal fluctuations of AMR as well as the lag in resistance following AM drug use. Nikolaou et al. (2006) created a framework that models the dynamics of a heterogenous bacterial population with distributed AMR and the influence of AM drug use on this dynamic.

Increasing emphasis on and adoption of strategies for combatting AMR, such as stewardship, infection control, and development of new AM drugs, could greatly impact the trajectory of future AMR cases and resulting burden. This is a complicating factor, particularly for long-term projections, as burden models must either rely on the current state of AMR prevention measures or predict future interventions and their degree of success. Systematic evaluations of the accuracy of previous AMR burden models are rare. Difficulties in estimating the current burden contribute to the challenge of evaluating historical models, and to the extent that present-day estimates of cases and deaths differ from the projected values, it may not be possible to remove the impact of, for example, new resistant strains that emerged during the projection period but were not accounted for in the model.

7 As shown in Table 1, H. pylori and H. influenzae are not included in CDC’s list but are classified by WHO as high and medium threats, respectively.

8 Other methods are available, such as using molecular methods to identify resistance genes.

9 For further discussion of the types of considerations organizations use when determining breakpoints, see https://www.eucast.org/clinical_breakpoints.